# List of Excluded Studies

## Not English – N=8

1 Auerbach B, Melzer C. Cross-linked hyaluronic acid in the treatment of osteoarthritis of the knee--results of a prospective randomized trial. Zentralbl Chir. Oct. 2002;127(10):895-899. [pmid: 12410458].
2 Bingol U, Yurtkuran M. Comparison of the clinical efficacy and adverse effects of two hyaluronan preparations with different molecular weights and a methyl prednisolone acetate in knee osteoarthritis ORIGINAL (NON-ENGLISH) TITLE Diz Osteoartritinde Iki Farkli{dotless} Molekul Agi{dotless}rli{dotless}kli{dotless} Hyaluronik Asit Preparati{dotless} ve Metil Prednisolon Asetat Preparati{dotless}ni{dotless}n Etki ve Yan Etkilerinin Klinik Olarak Karsi{dotless}lasti{dotless}ri{dotless}lmasi{dotless}. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi. 2013;59(3):189-200. 2013; FULL TEXT LINK http://dx.doi.org/10.4274/tftr.72687.
3 Bingöl Ü, Yurtkuran M. Comparison of the clinical efficacy and adverse effects of two hyaluronan preparations with different molecular weights and a methyl prednisolone acetate in knee osteoarthritis. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi. 2013;59(3):189-200.
4 Hashemi SM, Madadi F, Razavi S, et al. Intra-articular hyaluronic acid injections Vs. dextrose prolotherapy in the treatment of osteoarthritic knee pain. Tehran University Medical Journal. May. 2012;70(2):119-125.
5 Ostalowska A, Nowak D, Swiechowicz S, et al. Assessment of knee function and biochemical parameters of articular fluid and peripheral blood in gonarthrosis patients following intra-articular administration of hyaluronic acid. Pol Orthop Traumatol. 2013;78:173-181. [pmid: 23959433].
6 Oswald A, Gachter A. Acute local reaction after intra-articular injection of HYALAN G-F 20 (Synvisc) for treatment of gonarthrosis onset. Praxis (Bern 1994). Nov. 16. 2000;89(46):192931. [pmid: 11111412].
7 Pavelka K, Trc T, Karpas K, et al. Intra-articular treatment with Hyalgan in osteoarthrosis of the knee joint: experience in clinical practice in the Czech Republic. Acta Chir Orthop Traumatol Cech. 2002;69(5):302-307. [pmid: 12557601].
8 Swiechowicz S, Ostalowska A, Kasperczyk A, et al. Evaluation of hyaluronic acid intra-articular injections in the treatment of primary and secondary osteoarthritis of the knee. Pol Orthop Traumatol. 2012;77:105-109. [pmid: 23306296].

## Study Design– N=124

1 How effective are Hyalgan injections for arthritis?. Johns Hopkins Med Lett Health After 50. Mar. 1998;10(1):8. [pmid: 9600056].
2 How do the new injections for arthritis of the knee work, and who is a good candidate for this treatment?. Johns Hopkins Med Lett Health After 50. Jul. 2000;12(5):8. [pmid: 10879156].
3 Intra-articular injections for osteoarthritis of the knee. Med Lett Drugs Ther. Mar. 27. 2006;48(1231):25-27. [pmid: 16554699].
4 I've read that hyaluronic acid knee injections can be used to postpone knee surgery. Can hyaluronic acid in pill form provide the same relief?. Health News. Apr. 2006;12(4):16. [pmid: 16583498].
5 Summaries for patients. Viscosupplementation for knee osteoarthritis. Ann Intern Med. Aug. 7. 2012;157(3):I-36. [pmid: 22868857].
6 Knee injections offer minimal relief from arthritis pain. Harv Mens Health Watch. Sep. 2012;17(2):8. [pmid: 23050288].
7 Abate M, Schiavone C, Di Gregorio P, et al. Comparison between hyaluronic acid and platelet rich plasma in the treatment of hip and knee osteoarthritis: Preliminary results. Journal of Orthopaedics and Traumatology. October. 2013;14(1 SUPPL. 1):S17.
8 Abbott T, Altman RD, Dimeff R, et al. Do hyaluronic acid injections delay total knee replacement surgery?. Arthritis and Rheumatism. October. 2013;65(SUPPL 10):S910-S1.
9 Abrams GD, Cole BJ. Hyaluronic acid and platelet-rich plasma, intra-articular infiltration in the treatment of gonarthrosis. American Journal of Sports Medicine. 2013;41:5.
10 Adams ME. Acute local reactions after intraarticular hylan for osteoarthritis of the knee. J Rheumatol. May. 1996;23(5):944-945. author reply 6. [pmid: 8724316].
11 Ahadi T, Abtahi M. Platelet-rich plasma versus hyaluronic Acid. Arthroscopy. Nov. 2012;28(11):1585. author reply-6. [pmid: 23107248].
12 Allam A, El-Gazzar NM, El Sergany MAS, et al. Clinical and radiologic assessment of intra-articular hyaluronic acid injection versus ultrasound in management of primary osteoarthritis of the knee (a prospective study). Annals of the Rheumatic Diseases. 2013;72(SUPPL). Date of Publication: June 2013 CONFERENCE NAME Annual European Congress of Rheumatology of the European League Against Rheumatism, EULAR 2013 CONFERENCE LOCATION Madrid, Spain CONFERENCE DATE 12 to 2013-06-15(3):2013–06.
13 Allard S, O'Regan M. The role of elastoviscosity in the efficacy of viscosupplementation for osteoarthritis of the knee: a comparison of hylan G-F 20 and a lower-molecular-weight hyaluronan. Clin Ther. Jun. 2000;22(6):792-795. [pmid: 10929925].
14 Ammendolia A. Knee osteoarthritis and visco-supplementation: Advantages of the only one intra-articular infiltration with a cross linked high molecular weight hyaluronic acid. Journal of Orthopaedics and Traumatology. October. 2013;14(1 SUPPL. 1):S62.
15 Atamaz F, Kirazli Y, Akkoc Y. A comparison of two different intra-articular hyaluronan drugs and physical therapy in the management of knee osteoarthritis. Rheumatol Int. Aug. 2006;26(10):873-878. [pmid: 16416102].
16 Band PA. Intra-articular hyaluronic acid for treatment of osteoarthritis of the knee. JAMA. Mar. 24. 2004;291(12):1440. author reply 1–2. [pmid: 15039403].
17 Band PA. OARSI update on the evidence for osteoarthritis therapies: comment on the nomenclature used for intra-articular hyaluronan. Osteoarthritis Cartilage. Sep. 2010;18(9):1235. author reply 6. [pmid: 20633681].
18 Bellamy N. Hyaluronic acid and knee osteoarthritis. J Fam Pract. Nov. 2006;55(11):967-968. [pmid: 17115489].
19 Belzile EL, Cote M, Jacob MJ. The effects of combining viscosupplementation and knee bracing on pain reduction and increased function in patients with medial knee osteoarthritis. Clinical Journal of Sport Medicine. May. 2014;24(3):e49.
20 Bernstein J. Therapeutic effects of hyaluronic acid on osteoarthritis of the knee. J Bone Joint Surg Am. Nov. 2004;86-A(11):2567. author reply. [pmid: 15523034].
21 Briem K, Axe MJ, Snyder-Mackler L. Functional and perceived response to intra-articular hyaluronan injection in patients with knee osteoarthritis: persistence of treatment effects over 5 months. Knee Surg Sports Traumatol Arthrosc. Jul. 2009;17(7):763-769. [pmid: 19296086].
22 Bruyere O, Collette JH, Ethgen O, et al. Biochemical markers of bone and cartilage remodeling in prediction of longterm progression of knee osteoarthritis. J Rheumatol. May. 2003;30(5):1043-1050. [pmid: 12734904].
23 Brys DA. Corticosteroid compared with hyaluronic acid injections for the treatment of osteoarthritis of the knee. J Bone Joint Surg Am. Apr. 2004;86-A(4):874. author reply-5. [pmid: 15069162].
24 Bui B, Nguyen L. Efficacy of PRP injection in treatment of primary knee OA. International Journal of Rheumatic Diseases. April. 2014;17(SUPPL 1):35.
25 Campos GC, Rezende MU, Fruchi R, et al. Adding triamcinolone to viscosupplementation: One year outcome of randomized trial. Osteoarthritis and Cartilage. April. 2014;22(SUPPL 1):S198.
26 Cerza F, Carcangiu A. Hyaluronic Acid and Platelet-Rich Plasma, Intra-articular Infiltration in the Treatment of Gonarthrosis Response. American Journal of Sports Medicine. May. 2013;41(5):NP27-NP8. PMID:WOS:000318298300004.
27 Charalambous CP. Corticosteroid compared with hyaluronic acid injections for the treatment of osteoarthritis of the knee. J Bone Joint Surg Am. Apr. 2004;86-A(4):874. author reply. [pmid: 15069163].
28 Chen WL, Hsu WC, Lin YJ, et al. Comparison of intra-articular hyaluronic acid injections with transcutaneous electric nerve stimulation for the management of knee osteoarthritis: a randomized controlled trial. Arch Phys Med Rehabil. Aug. 2013;94(8):1482-1489. [pmid: 23628378].
29 Chevalier X. Forty-month trial suggests repeated hyaluronic acid injections for people with knee osteoarthritis may act as a long-term slow acting drug. Evid Based Med. Dec. 2012;17(6):188-189. [pmid: 22736661].
30 Chevalier X, Marini-Portugal A, Conrozier T. Comparison of hylan and hyaluronic acid for knee osteoarthritis: comment on the article by Juni et al. Arthritis Rheum. May. 2008;58(5):1560-1561. author reply 1–2. [pmid: 18438827].
31 Chou CL, Li HW, Lee SH, et al. Effect of intra-articular injection of hyaluronic acid in rheumatoid arthritis patients with knee osteoarthritis. J Chin Med Assoc. Aug. 2008;71(8):411-415. [pmid: 18772121].
32 Conrozier T, Mathieu P, Schott AM, et al. Factors predicting long-term efficacy of Hylan GF-20 viscosupplementation in knee osteoarthritis. Joint Bone Spine. Mar. 2003;70(2):128-133. [pmid: 12713857].
33 Coutts RD, Waddell DD. Viscosupplementation for osteoarthritis of the knee. Orthopedics. May. 2004;27(5):470-471. [pmid: 15181940].
34 Cubbage K. Does intra-articular hyaluronate decrease symptoms of osteoarthritis of the knee?. J Fam Pract. May. 2002;51(5):411. [pmid: 12019042].
35 Day RO, Brooks PM, Petersen M, et al. Efficacy and safety of intraarticular hyaluronic acid in osteoarthritis. Clinical Pharmacology and Therapeutics. 1999;65(2):172.
36 Diracoglu D, Alptekin K, Teksoz B, et al. Knee vs hip single-joint intra-articular hyaluronic acid injection in patients with both hip and knee osteoarthritis: a pilot study. Clin Rheumatol. Sep. 2009;28(9):1021-1024. [pmid: 19455363].
37 Divine JG, Shaffer MD. Use of viscosupplementation for knee osteoarthritis: an update. Curr Sports Med Rep. Sep-Oct. 2011;10(5):279-284. [pmid: 23531974].
38 Dreiser R, Rahhali N, Pibourdin JM, et al. Hyaluronic acid management of knee osteoarthritis: Impact on pain. Value in Health. May. 2010;13(3):A131.
39 Dubey V, Glazier RH. Intra-articular hyaluronic acid injections. Are they effective treatment for osteoarthritis of the knee?. Can Fam Physician. Apr. 2003;49:435-437. [pmid: 12729239].
40 Evaniew N, Simunovic N, Karlsson J. Cochrane in CORRR): Viscosupplementation for the treatment of osteoarthritis of the knee. Clin Orthop Relat Res. Jul. 2014;472(7):2028-2034. [pmid: 24218162].
41 Felson DT. Clinical practice. Osteoarthritis of the knee. N Engl J Med. Feb. 23. 2006;354(8):841-848. [pmid: 16495396].
42 Foti C, Cisari C, Carda S, et al. A prospective observational study of the clinical efficacy and safety of intra-articular sodium hyaluronate in synovial joints with osteoarthritis. Eur J Phys Rehabil Med. Sep. 2011;47(3):407-415. [pmid: 21946401].
43 Giarratana LS, Marelli BM, Crapanzano C, et al. A randomized double-blind clinical trial on the treatment of knee osteoarthritis: The efficacy of polynucleotides compared to standard hyaluronian viscosupplementation. Knee. Jun. 2014;21(3):661-668. [pmid: 24703391].
44 Gokmen F, Akbal A, Komurcu E, et al. Comparison of effects of combined physical therapy program and intra-articular treatment of hyaluronic acid on pain, balance and quality of life in patients with knee osteoarthritis ORIGINAL (NON-ENGLISH) TITLE Diz Osteoartritli Hastalarda Intraartikuler Hyaluronik Asit Tedavisi ile Kombine Fizik Tedavi Uygulamalarinin Anullri, Denge ve Yasam Kalitesi Uzerine Etkisinin Karsilastirilmasi. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi. April. 2013;59(SUPPL. 1):483.
45 Goldenberg MM. Pharmaceutical approval update. P and T. May. 2014;39(5):337-8+44. [pmid: 24883005].
46 Gordon MM, Hamilton J, Madhok R. Osteoarthritis of the knee. Lancet. Nov. 1. 1997;350(9087):1327-1328. [pmid: 9357434].
47 Grecomoro G, Piccione F, Letizia G. Therapeutic synergism between hyaluronic acid and dexamethasone in the intra-articular treatment of osteoarthritis of the knee: a preliminary open study. Curr Med Res Opin. 1992;13(1):49-55. [pmid: 1468245].
48 Guadilla J, Alvarez MS, Anitua E, et al. Plasma rich in growth factors (prgfendoret) in the treatment of symptomatic knee osteoarthritis: A randomized clinical trial. Arthroscopy -Journal of Arthroscopic and Related Surgery. October. 2013;29(10 SUPPL. 1):e71.
49 Gunendi Z. RE: TREATMENT OF KNEE JOINT OSTEOARTHRITIS WITH AUTOLOGOUS PLATELET-RICH PLASMA IN COMPARISON WITH HYALURONIC ACID. Am J Phys Med Rehabil. Jan. 2013;30. [pmid: 23370585].
50 Gunendi Z. Re: Treatment of knee joint osteoarthritis with autologous platelet-rich plasma in comparison with hyaluronic acid. Am J Phys Med Rehabil. Jan. 2014;93(1):95. [pmid: 23370585].
51 Hakshur K, Benhar I, Bar-Ziv Y, et al. The effect of hyaluronan injections into human knees on the number of bone and cartilage wear particles captured by bio-ferrography. Acta Biomater. Feb. 2011;7(2):848-857. [pmid: 20826234].
52 Hanson EC. Sodium hyaluronate--application in a community practice. Am J Orthop (Belle Mead NJ). Nov. 1999;28(11 Suppl):11-12. [pmid: 10587247].
53 Hasegawa M, Nakoshi Y, Tsujii M, et al. Changes in biochemical markers and prediction of effectiveness of intra-articular hyaluronan in patients with knee osteoarthritis. Osteoarthritis Cartilage. Apr. 2008;16(4):526-529. [pmid: 17951079].
54 Hatoum HT, Rosen JE, Fierlinger AL, et al. Assessment of the health-related quality of life impact of euflexxa (1% SODIUM HYALURONATE) using the short form (SF)-36 data collected in a randomized clinical trial. Osteoarthritis and Cartilage. April. 2013;21(SUPPL. 1):S246.
55 Henrotin Y, Hauzeur JP, Bruel P, et al. Intra-articular use of a medical device composed of hyaluronic acid and chondroitin sulfate (Structovial CS): effects on clinical, ultrasonographic and biological parameters. BMC Res Notes. 2012;5:407. [pmid: 22862789].
56 Huang MH, Yang RC, Lee CL, et al. Preliminary results of integrated therapy for patients with knee osteoarthritis. Arthritis Rheum. Dec. 15. 2005;53(6):812-820. [pmid: 16342083].
57 Hunter D. Intraarticular hylan was no better than hyaluronic acids for osteoarthritis of the knee. ACP J Club. Mar-Apr. 2008;148(2):42. [pmid: 18311872].
58 Huskisson E, Donnelly S. Is hyaluronic acid effective in patients with osteoarthritis of the knee?. West J Med. Oct. 2000;173(4):252. [pmid: 11017989].
59 Ishijima M, Nakamura T, Shimizu K, et al. Intra-articular hyaluronic acid injection versus oral non-steroidal anti-inflammatory drug for the treatment of knee osteoarthritis: a multi-center, randomized, open-label, non-inferiority trial. Arthritis Res Ther. Jan. 21. 2014;16(1):R18. [pmid: 24443804].
60 Ishijima M, Nakamura T, Shimizu K, et al. Different changes in the biomarker ctx-ii following intra-articular injection of high molecular weight hyaluronic acid and oral non-steroidal antiinflammatory drugs for patients with knee osteoarthritis: A multi-center randomized controlled study. Osteoarthritis and Cartilage. April. 2013;21(SUPPL. 1):S292.
61 Jeremic M. Therapeutic effect viscosuplementa and local infiltration of corticosteroid in patients with knee osteoarthritis. Osteoporosis International. April. 2014;25(SUPPL. 2):S433.
62 Juni P, Rutjes AW, da Costa BR, et al. Viscosupplementation for osteoarthritis of the knee. Ann Intern Med. Jan. 1. 2013;158(1):75. [pmid: 23277909].
63 Kandel L, Dolev Y, Rivkind G, et al. Safety and efficacy of MM-II, an intra-articular injection of liposomes, in moderate knee osteoarthritis. Prospective randomized double-blinded study. Osteoarthritis and Cartilage. April. 2014;22(SUPPL. 1):S193.
64 Kawasaki T, Kurosawa H, Ikeda H, et al. Therapeutic home exercise versus intraarticular hyaluronate injection for osteoarthritis of the knee: 6-month prospective randomized open-labeled trial. J Orthop Sci. Mar. 2009;14(2):182-191. [pmid: 19337810].
65 Kelly MA, Kurzweil PR, Lewallen DG, et al. New therapeutic options for managing the arthritic knee. Am J Orthop (Belle Mead NJ). Feb. 2004;33(2 Suppl):35-39. [pmid: 15005299].
66 Kevic S. Analysis of different therapies in the treatment of knee osteoarthritis. Osteoporosis International. April. 2014;25(SUPPL. 2):S379.
67 Khalaj N, Abu Osman N, Mokhtar A, et al. Postural stability and pain in obese ladies with mild knee osteoarthritis after intra-articular hyalgan injection. Osteoarthritis and Cartilage. April. 2014;22(SUPPL. 1):S100-S1.
68 Kon E, Filardo G, Di Martino A, et al. Platelet-rich plasma intra-articular injections versus visco-supplementation as a treatment for early osteoarthritis: A randomized double blind study. Journal of Orthopaedics and Traumatology. October. 2013;14(1 SUPPL. 1):S64-S5.
69 Kreder HJ, Huskinsson EC, Donnelly S. Is hyaluronic acid effective in patients with osteoarthritis of the knee?. Western Journal of Medicine. 2000;173(4):252. 2000; MEDLINE PMID 11017989 (http://www.ncbi.nlm.nih.gov/pubmed/11017989) FULL TEXT LINK http://dx.doi.org/10.1136/ewjm.173.4.252. [pmid: 11017988].
70 Kumahashi N, Naitou K, Nishi H, et al. Correlation of changes in pain intensity with synovial fluid adenosine triphosphate levels after treatment of patients with osteoarthritis of the knee with high-molecular-weight hyaluronic acid. Knee. Jun. 2011;18(3):160-164. [pmid: 20627733].
71 Kusayama Y, Akamatsu Y, Kumagai K, et al. Changes of the biomarkers in synovial fluid and clinical efficacy of intra-articular injection hyaluronic acid for patients with knee osteoarthritis. Osteoarthritis and Cartilage. April. 2014;22(SUPPL. 1):S478-S9.
72 Lambert C, Dubuc JE, Montell E, et al. Investigation of potential new targets for the diagnosis and/or the treatment of osteoarthritis. Annals of the Rheumatic Diseases. 2013;72(SUPPL). Date of Publication: June 2013 CONFERENCE NAME Annual European Congress of Rheumatology of the European League Against Rheumatism, EULAR 2013 CONFERENCE LOCATION Madrid, Spain CONFERENCE DATE 12 to 2013-06-15(3):2013–06.
73 LaPrade RF, Swiontkowski MF. New horizons in the treatment of osteoarthritis of the knee. JAMA. Mar. 10. 1999;281(10):876-878. [pmid: 10078464].
74 Leardini G, Mattara L, Franceschini M, et al. Intra-articular treatment of knee osteoarthritis. A comparative study between hyaluronic acid and 6-methyl prednisolone acetate. Clin Exp Rheumatol. Jul-Aug. 1991;9(4):375-381. [pmid: 1934686].
75 Lee SC, Rha DW, Chang WH. Rapid analgesic onset of intra-articular hyaluronic acid with ketorolac in osteoarthritis of the knee. J Back Musculoskelet Rehabil. 2011;24(1):31-38. [pmid: 21248398].
76 Lonner JH. A 57-year-old man with osteoarthritis of the knee. JAMA. Feb. 26. 2003;289(8):1016-1025. [pmid: 12597755].
77 Luchikhina LV, Mendel OI, Antonov DA. Knee osteoarthritis combination therapy with hyaluronic acid, chondroitine sulfate and glucosamine after arthroscopic lavage: Long-term results. Osteoarthritis and Cartilage. April. 2014;22(SUPPL. 1):S480.
78 Ludwig TE, McAllister JR, Lun VM, et al. Effect of flare reaction to intra-articular injection on cartilage lubricating ability of human synovial fluid. Osteoarthritis and Cartilage. April. 2013;21(SUPPL. 1):S299-S300.
79 Magilavy D, Polisson R, Murray C. Acute local reaction to intra-articular Hylan G-F 20 (Synvisc): part I. J Bone Joint Surg Am. Aug. 2003;85-A(8):1618-1619. author reply 9–20. [pmid: 12925653].
80 Magilavy D, Polisson R, Parenti D. Re: Karlsson et al. Comparison of two hyaluronan drugs and placebo in patients with knee osteoarthritis. A controlled, randomized, double-blind, parallel-design multicentre study. Rheumatology (Oxford). Oct. 2003;42(10):1262. author reply 3. [pmid: 14508044].
81 Magilavy DB, McPherson JM, Polisson R. Pseudoseptic reactions to Hylan viscosupplementation: diagnosis and treatment. Clin Orthop Relat Res. Dec. 2004;(429):349-350. author reply 50-1. [pmid: 15577509].
82 Mandell BF. Oil it where it squeaks: Evidence, experience, and osteoarthritis therapy. Cleveland Clinic Journal of Medicine. October. 2006;73(10):880. MEDLINE PMID 17044312 (http://www.ncbi.nlm.nih.gov/pubmed/17044312). [pmid: 17044312].
83 Maratea D, Fadda V, Trippoli S, et al. Viscosupplementation in patients with knee osteoarthritis: temporal trend of benefits assessed by meta-regression. Eur J Orthop Surg Traumatol. Jul. 2014;24(5):829-830. [pmid: 23715908].
84 Marcu IR, Patru S, Bighea A, et al. Efficacy of viscosupplementation with intra-articular hyaluronic acid in knee osteoarthritis. Osteoporosis International. April. 2014;25(SUPPL. 2):S422.
85 Marino AA, Dunn S, Waddell DD. Granulomatous inflammation after Hylan G-F 20 viscosupplementation of the knee. J Bone Joint Surg Am. Oct. 2003;85-A(10):2051-2052. author reply 2–3. [pmid: 14563818].
86 McAlindon TE, Bannuru RR. Osteoarthritis: Is viscosupplementation really so unsafe for knee OA?. Nat Rev Rheumatol. Nov. 2012;8(11):635-636. [pmid: 22964536].
87 Miltner O, Schneider U, Siebert CH, et al. Efficacy of intraarticular hyaluronic acid in patients with osteoarthritis--a prospective clinical trial. Osteoarthritis Cartilage. Sep. 2002;10(9):680-686. [pmid: 12202120].
88 Miroljub MD, Grujic M. Efficacy of intraarticular application of hyaluronate in comparison to intraarticular application of betamethasone in the treatment of primary osteoarthritis of the knee. Annals of the Rheumatic Diseases. 2013;72(SUPPL). Date of Publication: June 2013 CONFERENCE NAME Annual European Congress of Rheumatology of the European League Against Rheumatism, EULAR 2013 CONFERENCE LOCATION Madrid, Spain CONFERENCE DATE 12 to 2013-06-15(3):2013–06.
89 Nahlaer G, Metelmann H, Sperber H. Treating osteoarthritis of the knee with a homeopathic preparation: results of a randomized, controlled, clinical trial in comparison th hyaluronic acid. Biomed Ther. 1998:186-191.
90 Nakata K, Nishiike J, Nishiike A. Increased risk of severe acute inflammatory reactions to chemically cross-linked hyaluronic acid among Japanese patients with osteoarthritis of the knee. International Journal of Rheumatic Diseases. September. 2013;16(SUPPL. 1):87.
91 Navarro-Sarabia F, Herrero-Beaumont G. Viscosupplementation for osteoarthritis of the knee. Ann Intern Med. Jan. 1. 2013;158(1):74-75. [pmid: 23277908].
92 O'Hanlon D. Acute local reactions after intraarticular hylan for osteoarthritis of the knee. J Rheumatol. May. 1996;23(5):945-946. [pmid: 8724318].
93 Pasquale M, Louder A, Cheung R, et al. Knee and hip replacements: Prevalence and healthcare utilization and costs pre-and post-surgery for Medicare Advantage members. Journal of Pain. April. 2014;15(4 SUPPL. 1):S97.
94 Paterson K, Nicholls M, Bates D. Intra-articular injection of platelet-rich plasma in patients with knee osteoarthritis: A randomised controlled pilot study. Journal of Science and Medicine in Sport. December. 2013;16(SUPPL. 1):e90.
95 Perez-Guijo V, Garrido-Castro JL, Collantes-Estevez E, et al. Assessment of postural stability in patients with knee osteoarthritis: A pilot study. Annals of the Rheumatic Diseases. 2013;72(SUPPL). Date of Publication: June 2013 CONFERENCE NAME Annual European Congress of Rheumatology of the European League Against Rheumatism, EULAR 2013 CONFERENCE LOCATION Madrid, Spain CONFERENCE DATE 12 to 2013-06-15(3):2013–06.
96 Petrella R, Petrella M, Decaria J. A randomized double-blind control trial of intra-articular hyaluronic acid:Botulinum toxin type a versus placebo for mild to moderate knee oa. Annals of the Rheumatic Diseases. 2013;72(SUPPL). Date of Publication: June 2013 CONFERENCE NAME Annual European Congress of Rheumatology of the European League Against Rheumatism, EULAR 2013 CONFERENCE LOCATION Madrid, Spain CONFERENCE DATE 12 to 2013-06-15(3):2013–06.
97 Petrella RJ, Eamans P, Alleyne J, et al. A prospective, multi-center, randomized, double-blind feasibility study to evaluate the safety and performance of hydros joint therapy and hydrosta joint therapy for management of pain associated with osteoarthritis in the knee. Osteoarthritis and Cartilage. April. 2012;20(SUPPL. 1):S172-S3.
98 Petrella RJ, Gill D, Wakeford C. Health care resource utilization in the management of knee osteoarthritis with hyaluronic acid in a Canadian real-world population. Value in Health. May. 2014;17(3):A49.
99 Petrella RJ, Gill DP, Wakeford C. Prevalence of knee osteoarthritis and impact of hyaluronic acid treatment on pain and mobility in a Canadian real-world population. Osteoarthritis and Cartilage. April. 2014;22(SUPPL. 1):S222.
100 Poggioli F, Taverriti T, Crapanzano C, et al. YKL-40 (versus comp) as a new marker of knee osteoarthritis. American Journal of Pathology. September. 2012;181(3 SUPPL. 1):S4.
101 Polacco A, Beomonte Zobel B, Polacco M, et al. The effect of intra-articular hyaluronic acid (Sinovial® One) on knee osteoarthritis: A preliminary study. European Journal of Inflammation. 2013;11(3):847-853.
102 Puhl W, Scharf P. Intra-articular hyaluronan treatment for osteoarthritis. Ann Rheum Dis. Jul. 1997;56(7):441. [pmid: 9486013].
103 Punzi L. Intra-articular sodium hyaluronate reduces pain and improves function in osteoarthritis of knee. Clin Exp Rheumatol. Jan-Feb. 2001;19(1):9-10. [pmid: 11247334].
104 Radenne F. Pain relief, functional recovery and associated medical treatments reduction in large-scale population with osteoarthritis receiving injections of viscosupplement incorporating high concentration of sorbitol. Osteoarthritis and Cartilage. April. 2014;22(SUPPL. 1):S407.
105 Rezende MU, Campos GC, Pailo AF, et al. Evaluation of the effect of adding corticosteroid to viscosupplementation: A prospective and randomized study. Osteoporosis International. March. 2012;23(SUPPL. 2):S132-S3.
106 Roth R, Kipshoven C. Efficacy of an intra-articular treatment of osteoarthritis of the knee with hyaluronan (GO-ON(registered trademark)). Osteoporosis International. March. 2012;23(SUPPL. 2):S180-S1.
107 Samikrishnan P. Nested prospective open case-control comparative study of intra-articular injection of low-dose versus high-dose viscosupplement given with and without an aid of image intensifier and the frequency of use when given with and without steroid in osteoarthritis of knees. Indian Journal of Rheumatology. November. 2011;6(3 SUPPL. 1):S3.
108 Sanchez M, Anitua E, Fiz N, et al. Plasma rich in growth factors (PRGF-Endoret) in the treatment of symptomatic knee osteoarthritis: A randomized clinical trial. Osteoarthritis and Cartilage. April. 2012;20(SUPPL. 1):S172.
109 Sheytanov I, Rashkov R, Petranova T, et al. Intraarticular treatment of painful knee osteoarthritis: Clinical and sonographic evaluation. Osteoporosis International. April. 2013;24(1 SUPPL. 1):S103-S4.
110 Sindel D, Koseonulllu F, Akyuz G, et al. Long-term efficacy and safety of intra-articular sodium hyaluronate injections in knee osteoarthritis: A prospective, randomized, double-blind, placebo-controlled trial ORIGINAL (NON-ENGLISH) TITLE Diz osteoartritinde Intra-artikuler sodyum hyaluronat enjeksiyonunun uzun donemde etkinlik ve guvenilirlinulli: Prospektif, randomize, cnullift kor, plasebo kontrollu cnullaliflma. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi. 2011;57(SUPPL. 1):131. 2011.
111 Skakic V, Jovanovic J, Skakic A. Intraarticular hyaluronic acid treatment in osteoarthritis of the knee. Osteoporosis International. April. 2014;25(SUPPL. 2):S385.
112 Spakova T. RE: TREATMENT OF KNEE JOINT OSTEOARTHRITIS WITH AUTOLOGOUS PLATELET-RICH PLASMA IN COMPARISON WITH HYALURONIC ACID. Am J Phys Med Rehabil. 2013. Jan. 30.
113 Spakova T. Re: Treatment of knee joint osteoarthritis with autologous platelet-rich plasma in comparison with hyaluronic acid. Am J Phys Med Rehabil. Jan. 2014;93(1):95. [pmid: 24501778].
114 Vad V, Solomon J. Osteoarthritis case study. Orthopedics. Feb. 2005;28(2 Suppl):s221-s225. [pmid: 15747610].
115 Vanelli R, Costa P, Rossi SM, et al. Efficacy of intra-articular polynucleotides in the treatment of knee osteoarthritis: a randomized, double-blind clinical trial. Knee Surg Sports Traumatol Arthrosc. Jul. 2010;18(7):901-907. [pmid: 20111953].
116 Vaskova NV. Early efficacyand safety of hyaluronic acid of different molecularweights in knee osteoarthritis. Osteoporosis International. April. 2014;25(SUPPL. 2):S315.
117 Vincent HK, Conrad B, Lamb KM, et al. Hyaluronic acid viscosupplementation effects on functional mobility in older adults with knee pain. PM and R. September. 2011;3(10 SUPPL. 1):S213.
118 Williams FM, Spector TD. Are intra-articular injections of hylan more effective than injections of hyaluronic acid for knee osteoarthritis?. Nat Clin Pract Rheumatol. Aug. 2008;4(8):400-401. [pmid: 18594492].
119 Wolfova L, Svik K, Pravda M, et al. Material on the basis of partially crosslinked solution of HA derivative for synovial fluid viscosupplementation. Osteoarthritis and Cartilage. April. 2014;22(SUPPL. 1):S479.
120 Zardawi IM. Granulomatous inflammation after Hylan G-F 20 viscosupplementation of the knee. J Bone Joint Surg Am. Dec. 2003;85-A(12):2484. author reply-5. [pmid: 14668528].
121 Zeni J, Axe M, Beeson H, et al. Comparison of two hyaluronic acid formulations on functional outcomes in patients with knee osteoarthritis. Osteoarthritis and Cartilage. September. 2011;19(SUPPL. 1):S141.
122 Zeni J, Snyder-Mackler L, Axey M. Comparative effectiveness of two hyaluronic acid formulations on perceived functional performance. Osteoarthritis and Cartilage. April. 2013;21(SUPPL. 1):S300-S1.
123 Zhang H, Zhang K, Zhang XL, et al. Comparison of two hyaluronic acid formulations for safety and efficacy (CHASE) study of knee osteoarthritis: A multicenter, randomized, double-blind, 26 week noninferiority trial comparing DUROLANE(registered trademark) to ARTZ(registered trademark). Osteoarthritis and Cartilage. April. 2014;22(SUPPL. 1):S397.
124 Zorzi C, Rigotti S, Giordan N, et al. Randomized, single center, observer-blind, parallelgroup trial to evaluate the safety and effectiveness of HYADD(registered trademark) 4-G a viscoelastic hydrogel, for the treatment of meniscus tear. Osteoarthritis and Cartilage. April. 2014;22(SUPPL. 1):S194.

## Participants -N=10

1 Altman RD. Non-avian-derived hyaluronan for the treatment of osteoarthritis of the knee. Expert Rev Clin Immunol. Jan. 2010;6(1):21-27. [pmid: 20383887].
2 Askari A, Chahine KAN. Observational study on intra/periarticular injections in North Jordan [1]. Clinical and Experimental Rheumatology. 2002;20(2):255-256. 2002; MEDLINE PMID 12051409 (http://www.ncbi.nlm.nih.gov/pubmed/12051409). [pmid: 12051409].
3 Balazs EA. Analgesic effect of elastoviscous hyaluronan solutions and the treatment of arthritic pain. Cells Tissues Organs. 2003;174(1–2):49-62. [pmid: 12784041].
4 Bellamy N, Bell MJ, Goldsmith CH, et al. Evaluation of WOMAC 20, 50, 70 response criteria in patients treated with hylan G-F 20 for knee osteoarthritis. Ann Rheum Dis. Jun. 2005;64(6):881-885. [pmid: 15564311].
5 Bellamy N, Bell MJ, Pericak D, et al. BLISS index for analyzing knee osteoarthritis trials data. J Clin Epidemiol. Feb. 2007;60(2):124-132. [pmid: 17208118].
6 Dahlberg L, Lohmander LS, Ryd L. Intraarticular injections of hyaluronan in patients with cartilage abnormalities and knee pain. A one-year double-blind, placebo-controlled study. Arthritis Rheum. Apr. 1994;37(4):521-528. [pmid: 8147929].
7 Grootendorst P, Marshall D, Pericak D, et al. A model to estimate health utilities index mark 3 utility scores from WOMAC index scores in patients with osteoarthritis of the knee. J Rheumatol. Mar. 2007;34(3):534-542. [pmid: 17343301].
8 Hamburger M, Settles M, Teutsch J. Identification of an immunogenic candidate for the elicitation of severe acute inflammatory reactions (SAIRs) to hylan G-F 20. Osteoarthritis and Cartilage. March. 2005;13(3):266-268. MEDLINE PMID 15727894 (http://www.ncbi.nlm.nih.gov/pubmed/15727894) FULL TEXT LINK http://dx.doi.org/10.1016/j.joca.2004.11.009. [pmid: 15727894].
9 Ioannidou D, Krasagakis K, Stefanidou M, et al. Erythema annulare centrifugum and osteoarthritis treated with hyaluronic acid. Clin Exp Dermatol. Nov. 2002;27(8):720-722. [pmid: 12472560].
10 Kim NH, Han CD, Lee HM, et al. Effect of sodium hyaluronate on prevention of osteoarthritis. Yonsei Medical Journal. 1991;32(2):139-146. [pmid: 1949917].

## Interventions not of interest - N=7

1 Berger A, Bozic K, Stacey B, et al. Patterns of pharmacotherapy and health care utilization and costs prior to total hip or total knee replacement in patients with osteoarthritis. Arthritis and Rheumatism. August. 2011;63(8):2268-2275. MEDLINE PMID 21520012 (http://www.ncbi.nlm.nih.gov/pubmed/21520012) FULL TEXT LINK http://dx.doi.org/10.1002/art.30417. [pmid: 21520012].
2 Burki V, Paternotte S, Dougados M, et al. Rapidly destructive tibiofemoral knee osteoarthritis: Clinicoradiological presentation and outcome after global medical treatment including non-arthroscopic joint lavage plus corticosteroid injection. A single center retrolective study. Joint Bone Spine. 2013. Jul. 9. [pmid: 23845381].
3 Crawford DC, Miller LE, Block JE. Conservative management of symptomatic knee osteoarthritis: A flawed strategy?. Orthopedic Reviews. 12. 2013;5(1):5-10. FULL TEXT LINK http://dx.doi.org/10.4081/or.2013.e2.
4 Huang MH, Lin YS, Yang RC, et al. A Comparison of Various Therapeutic Exercises on the Functional Status of Patients With Knee Osteoarthritis. Seminars in Arthritis and Rheumatism. 2003;32(6):398-406. [pmid: 12833248].
5 Kalman DS, Heimer M, Valdeon A, et al. Effect of a natural extract of chicken combs with a high content of hyaluronic acid (Hyal-Joint) on pain relief and quality of life in subjects with knee osteoarthritis: a pilot randomized double-blind placebo-controlled trial. Nutr J. 2008;7:3. [pmid: 18208600].
6 Nelson FR, Zvirbulis RA, Zonca B, et al. Erratum to: The effects of an oral preparation containing hyaluronic acid (Oralvisc) on obese knee osteoarthritis patients determined by pain, function, bradykinin, leptin, inflammatory cytokines, and heavy water analyses. Rheumatol Int. 2014. Jul. 2. [pmid: 24985363].
7 Wong KL, Lee KB, Tai BC, et al. Injectable cultured bone marrow-derived mesenchymal stem cells in varus knees with cartilage defects undergoing high tibial osteotomy: a prospective, randomized controlled clinical trial with 2 years' follow-up. Arthroscopy. Dec. 2013;29(12):2020-2028. [pmid: 24286801].

## Outcomes not of interest -N=103

1 Intra-articular viscosupplementation with hylan g-f 20 to treat osteoarthritis of the knee: an evidence-based analysis. Ont Health Technol Assess Ser. 2005;5(10):1-66. [pmid: 23074461].
2 Special report: intra-articular hyaluronan for osteoarthritis of the knee. Technol Eval Cent Assess Program Exec Summ. Feb. 2005;19(17):1-2. [pmid: 15714700].
3 Intra-articular hyaluronic acid injection: not for gonarthrosis. Prescrire Int. Oct. 2013;22(142):248-249. [pmid: 24298599].
4 Abate M, Pelotti P, De Amicis D, et al. Viscosupplementation with hyaluronic acid in hip osteoarthritis (a review). Ups J Med Sci. 2008;113(3):261-277. [pmid: 18991239].
5 Al-Omran A, Azam Q. Efficacy of viscosupplementation in knee osteoarthritis: A clinical trial of three agents. Bahrain Medical Bulletin. 2014.
6 Anandacoomarasamy A, Bagga H, Ding C, et al. Predictors of clinical response to intraarticular Hylan injections --a prospective study using synovial fluid measures, clinical outcomes, and magnetic resonance imaging. J Rheumatol. Apr. 2008;35(4):685-690. [pmid: 18278831].
7 Arrich J, Piribauer F, Mad P, et al. Intra-articular hyaluronic acid for the treatment of osteoarthritis of the knee: systematic review and meta-analysis. CMAJ. Apr. 12. 2005;172(8):1039-1043. [pmid: 15824412].
8 Baek SH, Kim SY. Pharmacologic treatment of osteoarthritis. Journal of the Korean Medical Association. Dec. 2013;56(12):1123-1131. PMID:WOS:000328803200010.
9 Bannuru RR, Natov NS, Dasi UR, et al. Therapeutic trajectory following intra-articular hyaluronic acid injection in knee osteoarthritis: Meta-analysis. Osteoarthritis and Cartilage. October. 2010;18(SUPPL. 2):S242-S3.
10 Bannuru RR, Natov NS, Dasi UR, et al. Therapeutic trajectory following intra-articular hyaluronic acid injection in knee osteoarthritis--meta-analysis. Osteoarthritis Cartilage. Jun. 2011;19(6):611-619. [pmid: 21443958].
11 Bannuru RR, Natov NS, Obadan IE, et al. Relative efficacy of hyaluronic acid versus corticosteroids in the treatment of knee osteoarthritis: Meta-analysis. Osteoarthritis and Cartilage. September. 2009;17(SUPPL. 1):S269-S70.
12 Bannuru RR, Vaysbrot EE, McIntyre LF. Did the American Academy of Orthopaedic Surgeons osteoarthritis guidelines miss the mark?. Arthroscopy. Jan. 2014;30(1):86-89. [pmid: 24384274].
13 Bellamy N, Campbell J, Robinson V, et al. Viscosupplementation for the treatment of osteoarthritis of the knee. Cochrane Database Syst Rev. 2006;(2):CD005321. [pmid: 16625635].
14 Bellamy N, Campbell J, Robinson V, et al. Intraarticular corticosteroid for treatment of osteoarthritis of the knee. Cochrane Database Syst Rev. 2006;(2):CD005328. [pmid: 16625636].
15 Belo JN, Berger MY, Reijman M, et al. Prognostic factors of progression of osteoarthritis of the knee: a systematic review of observational studies. Arthritis Rheum. Feb. 15. 2007;57(1):1326. [pmid: 17266080].
16 Bert JM, Bert TM. Nonoperative treatment of unicompartmental arthritis: from bracing to injection. Clin Sports Med. Jan. 2014;33(1):1-10. [pmid: 24274841].
17 Brander VA, Stadler TS. Functional improvement with hylan G-F 20 in patients with knee osteoarthritis. Phys Sportsmed. Oct. 2009;37(3):38-48. [pmid: 20048527].
18 Bruyere O, Burlet N, Delmas PD, et al. Evaluation of symptomatic slow-acting drugs in osteoarthritis using the GRADE system. Bmc Musculoskeletal Disorders. 2008. Dec. 9. PMID:WOS:000263229200001.
19 Bruyere O, Cooper C, Pelletier JP, et al. An algorithm recommendation for the management of knee osteoarthritis in Europe and internationally: A report from a task force of the European Society for Clinical and Economic Aspects of Osteoporosis and Osteoarthritis (ESCEO). Semin Arthritis Rheum. 2014. May. 14. [pmid: 24953861].
20 Brzusek D, Petron D. Treating knee osteoarthritis with intra-articular hyaluronans. Curr Med Res Opin. Dec. 2008;24(12):3307-3322. [pmid: 18954498].
21 CADTH Rapid Response Service. Viscosupplementation for the Treatment of Osteoarthritis of the Knee: Clinical Effectiveness and Guidelines. 13. February. 2014.
22 Campbell J, Bellamy N, Gee T. Differences between systematic reviews/meta-analyses of hyaluronic acid/hyaluronan/hylan in osteoarthritis of the knee. Osteoarthritis Cartilage. Dec. 2007;15(12):1424-1436. [pmid: 17448701].
23 Cerza F, Carni S, Carcangiu A, et al. Comparison between hyaluronic acid and platelet-rich plasma, intra-articular infiltration in the treatment of gonarthrosis. Am J Sports Med. Dec. 2012;40(12):2822-2827. [pmid: 23104611].
24 Chard J, Lohmander S, Smith C, et al. Osteoarthritis of the knee. Clin Evid. Dec. 2005;(14):1506-1522. [pmid: 16620461].
25 Chen R, Chen M, Kang M, et al. The design and protocol of heat-sensitive moxibustion for knee osteoarthritis: a multicenter randomized controlled trial on the rules of selecting moxibustion location. BMC Complement Altern Med. 2010;10:32. [pmid: 20576162].
26 Cheng OT, Souzdalnitski D, Vrooman B, et al. Evidence-based knee injections for the management of arthritis. Pain Med. Jun. 2012;13(6):740-753. [pmid: 22621287].
27 Chou CW, Lue KH, Lee HS, et al. Hylan G-F 20 has better pain relief and cost-effectiveness than sodium hyaluronate in treating early osteoarthritic knees in Taiwan. J Formos Med Assoc. Aug. 2009;108(8):663-672. [pmid: 19666354].
28 Conrozier T, Balblanc JC, Richette P, et al. Early effect of hyaluronic acid intra-articular injections on serum and urine biomarkers in patients with knee osteoarthritis: An open-label observational prospective study. J Orthop Res. May. 2012;30(5):679-685. [pmid: 22025307].
29 Curran MP. Hyaluronic acid (Supartz(R)): a review of its use in osteoarthritis of the knee. Drugs Aging. Nov. 1. 2010;27(11):925-941. [pmid: 20964466].
30 Decaria J, Petrella R, Petrella R, et al. Effect of intra-articular hyaluronic acid on gait variability in older adults with knee osteoarthritis. J Am Geriatr Soc. May. 2011;59(5):949-951. [pmid: 21568973].
31 Divine JG, Zazulak BT, Hewett TE. Viscosupplementation for knee osteoarthritis: a systematic review. Clin Orthop Relat Res. Feb. 2007;455:113-122. [pmid: 17159579].
32 Divine PG, Zazulak BT, Hewett TE. Viscosupplementation for knee osteoarthritis: a systematic review. Clinical Orthopaedics and Related Research. Jun. 2007;(459):283. PMID:WOS:000247085300046. [pmid: 17159573].
33 Espallargues M, Pons JM. Efficacy and safety of viscosupplementation with Hylan G-F 20 for the treatment of knee osteoarthritis: a systematic review. Int J Technol Assess Health Care. Winter. 2003;19(1):41-56. [pmid: 12701938].
34 Evaniew N, Hanson B, Winemaker M. Viscosupplementation for knee osteoarthritis: current evidence and recommendations. J Long Term Eff Med Implants. 2013;23(2–3):151-159. [pmid: 24579855].
35 Evaniew N, Simunovic N, Karlsson J. Cochrane in CORR®: Viscosupplementation for the Treatment of Osteoarthritis of the Knee Article in Press. Clinical Orthopaedics and Related Research. 2013:1-7.
36 Evans CH, Kraus VB, Setton LA. Progress in intra-articular therapy. Nature Reviews Rheumatology. January. 2014;10(1):11-22. [pmid: 24189839].
37 Gallagher B, Tjoumakaris FP, Harwood MI, et al. Chondroprotection and the Prevention of Osteoarthritis Progression of the Knee: A Systematic Review of Treatment Agents. Am J Sports Med. 2014. May. 27. [pmid: 24866892].
38 Goldberg VM, Buckwalter JA. Hyaluronans in the treatment of osteoarthritis of the knee: evidence for disease-modifying activity. Osteoarthritis Cartilage. Mar. 2005;13(3):216-224. [pmid: 15727888].
39 Goorman SD, Watanabe TK, Miller EH, et al. Functional outcome in knee osteoarthritis after treatment with hylan G-F 20: a prospective study. Arch Phys Med Rehabil. Apr. 2000;81(4):479-483. [pmid: 10768539].
40 Habib G, Artul S, Chernin M, et al. The effect of intra-articular injection of betamethasone acetate/betamethasone sodium phosphate at the knee joint on the hypothalamic-pituitary-adrenal axis: A case-controlled study. Journal of Investigative Medicine. 2013;61(7):1104-1107. 2013. [pmid: 24013525].
41 Habib G, Jabbour A, Artul S, et al. Intra-articular methylprednisolone acetate injection at the knee joint and the hypothalamic-pituitary-adrenal axis: a randomized controlled study. Clin Rheumatol. 2013. Aug. 28. [pmid: 23982564].
42 Habib G, Khazin F, Jabbour A, et al. Simultaneous bilateral knee injection of methylprednisolone acetate and the hypothalamic-pituitary adrenal axis: a single-blind case-control study. J Investig Med. Mar. 2014;62(3):621-626. [pmid: 24430212].
43 Hamburger MI, Lakhanpal S, Mooar PA, et al. Intra-articular hyaluronans: a review of product-specific safety profiles. Semin Arthritis Rheum. Apr. 2003;32(5):296-309. [pmid: 12701040].
44 Hammesfahr JF, Knopf AB, Stitik T. Safety of intra-articular hyaluronates for pain associated with osteoarthritis of the knee. Am J Orthop (Belle Mead NJ). Jun. 2003;32(6):277-283. [pmid: 12834190].
45 Hochberg MC, Altman RD, April KT, et al. American College of Rheumatology 2012 recommendations for the use of nonpharmacologic and pharmacologic therapies in osteoarthritis of the hand, hip, and knee. Arthritis Care Res (Hoboken). Apr. 2012;64(4):465-474. [pmid: 22563589].
46 Ickinger C, Tikly M. Current approach to diagnosis and management of osteoarthritis. South African Family Practice. 2014;56(2):102-108.
47 Jevsevar DS. Treatment of osteoarthritis of the knee: evidence-based guideline, 2nd edition. J Am Acad Orthop Surg. Sep. 2013;21(9):571-576. [pmid: 23996988].
48 Jones AC, Pattrick M, Doherty S, et al. Intra-articular hyaluronic acid compared to intra-articular triamcinolone hexacetonide in inflammatory knee osteoarthritis. Osteoarthritis Cartilage. Dec. 1995;3(4):269-273. [pmid: 8689462].
49 Jordan KM, Arden NK, Doherty M, et al. EULAR Recommendations 2003: An evidence based approach to the management of knee osteoarthritis: Report of a Task Force of the Standing Committee for International Clinical Studies Including Therapeutic Trials (ESCISIT). Annals of the Rheumatic Diseases. December. 2003;62(12):1145-1155. MEDLINE PMID 14644851 (http://www.ncbi.nlm.nih.gov/pubmed/14644851) FULL TEXT LINK http://dx.doi.org/10.1136/ard.2003.011742. [pmid: 14644851].
50 Kang ML, Im GI. Drug delivery systems for intra-articular treatment of osteoarthritis. Expert Opinion on Drug Delivery. Feb. 2014;11(2):269-282. PMID:WOS:000329872400008. [pmid: 24308404].
51 Kobayashi K, Matsuzaka S, Yoshida Y, et al. The effects of intraarticularly injected sodium hyaluronate on levels of intact aggrecan and nitric oxide in the joint fluid of patients with knee osteoarthritis. Osteoarthritis Cartilage. Jul. 2004;12(7):536-542. [pmid: 15219568].
52 Kwan-Morley J, Clayburne G, Schumacher HR. Synovial fluid findings in a patient after hylan GF 20 injection. J Clin Rheumatol. Apr. 2008;14(2):120. [pmid: 18391685].
53 Lester DK, Zhang K. Gait analysis of knee arthritis treated with hyaluronic acid. J Arthroplasty. Dec. 2010;25(8):1290-1294. [pmid: 20022450].
54 Li CS, Ayeni OR, Sprague S, et al. Conservative treatments, surgical treatments, and the KineSpring(R) Knee Implant system for knee osteoarthritis: a systematic review. J Long Term Eff Med Implants. 2013;23(2–3):105-149. [pmid: 24579854].
55 Lo GH, LaValley M, McAlindon T, et al. Intra-articular hyaluronic acid in treatment of knee osteoarthritis: a meta-analysis. JAMA. Dec. 17. 2003;290(23):3115-3121. [pmid: 14679274].
56 Losina E, Dervan EE, Daigle ME, et al. Studies of pain management in osteoarthritis: Bedside to policy. Osteoarthritis and Cartilage. September. 2013;21(9):1264-1271. FULL TEXT LINK http://dx.doi.org/10.1016/j.joca.2013.04.013. [pmid: 23973140].
57 Maheu E. Hyaluronic acid intra-articular injections in knee osteoarthritis (OA): Who should be treated?. Osteoporosis International. April. 2013;24(1 SUPPL. 1):S386-S7.
58 Marino AA, Waddell DD, Kolomytkin OV, et al. Assessment of immunologic mechanisms for flare reactions to Synvisc. Clin Orthop Relat Res. Jan. 2006;442:187-194. [pmid: 16394759].
59 McAlindon TE, Bannuru RR, Sullivan MC, et al. OARSI guidelines for the non-surgical management of knee osteoarthritis. Osteoarthritis Cartilage. 2014. Jan. 24. [pmid: 24462672].
60 Meccariello L, Cioffi S, Franzese R, et al. Intraarticular knee joint injection: Hyaluronic acid vs polynucleotides. EuroMediterranean Biomedical Journal. 2013;8:35-41.
61 Medina JM, Thomas A, Denegar CR. Knee osteoarthritis: should your patient opt for hyaluronic acid injection?. J Fam Pract. Aug. 2006;55(8):669-675. [pmid: 16882439].
62 Migliore A, Giovannangeli F, Granata M, et al. Hylan g-f 20: review of its safety and efficacy in the management of joint pain in osteoarthritis. Clin Med Insights Arthritis Musculoskelet Disord. 2010;3:55-68. [pmid: 21151854].
63 Mobasheri A. The future of osteoarthritis therapeutics: Emerging biological therapy. Current Rheumatology Reports. 2013;15(12).
64 Modawal A, Ferrer M, Choi HK, et al. Hyaluronic acid injections relieve knee pain. J Fam Pract. Sep. 2005;54(9):758-767. [pmid: 16144589].
65 Monseau AJ, Singh Nizran P. Common Injections in Musculoskeletal Medicine. Primary Care -Clinics in Office Practice. December. 2013;40(4):987-1000. [pmid: 24209729].
66 Oka H, Akune T, Muraki S, et al. The mid-term efficacy of intra-articular hyaluronic acid injections on joint structure: a nested case control study. Mod Rheumatol. Jul. 2013;23(4):722-728. [pmid: 22915220].
67 Pai SK, Allgar V, Giannoudis PV. Are intra-articular injections of Hylan G-F 20 efficacious in painful osteoarthritis of the knee? A systematic review & meta-analysis. Int J Clin Pract. 2014. May. 5. [pmid: 24797624].
68 Payne MW, Petrella RJ. Viscosupplementation effect on proprioception in the osteoarthritic knee. Arch Phys Med Rehabil. May. 2000;81(5):598-603. [pmid: 10807098].
69 Pendleton A, Arden N, Dougados M, et al. EULAR recommendations for the management of knee osteoarthritis: Report of a task force of the standing committee for international clinical studies including therapeutic trials (ESCISIT). Annals of the Rheumatic Diseases. 2000;59(12):936-944. 2000; MEDLINE PMID 11087696 (http://www.ncbi.nlm.nih.gov/pubmed/11087696) FULL TEXT LINK http://dx.doi.org/10.1136/ard.59.12.936. [pmid: 11087696].
70 Pintan GF, de Oliveira AS Jr, Lenza M, et al. Update on biological therapies for knee injuries: osteoarthritis. Curr Rev Musculoskelet Med. 2014. Jul. 2. [pmid: 24986668].
71 Ray TR. Using viscosupplementation to treat knee osteoarthritis. Phys Sportsmed. Nov. 2013;41(4):16-24. [pmid: 24231593].
72 Reginster JY. The general approach to the patient with osteoarthritis: Is a treatment algorithm feasible?. Osteoporosis International. April. 2013;24(1 SUPPL. 1):S385.
73 Reichenbach S, Blank S, Rutjes AW, et al. Hylan versus hyaluronic acid for osteoarthritis of the knee: a systematic review and meta-analysis. Arthritis Rheum. Dec. 15. 2007;57(8):1410-1418. [pmid: 18050181].
74 Rodriguez-Merchan EC. Intra-articular Injections of Hyaluronic Acid and Other Drugs in the Knee Joint. HSS Journal. 2013;9(2):180-182. [pmid: 24426865].
75 Rossini M, Viapiana O, Ramonda R, et al. Intra-articular clodronate for the treatment of knee osteoarthritis: dose ranging study vs hyaluronic acid. Rheumatology (Oxford). Jul. 2009;48(7):773-778. [pmid: 19406908].
76 Samson DJ, Grant MD, Ratko TA, et al. Treatment of primary and secondary osteoarthritis of the knee. Evid Rep Technol Assess (Full Rep). Sep. 2007;(157):1-157. [pmid: 18088162].
77 Schumacher HR, Paul C, Hitchon CA, et al. Hyaluronate effects on synovium and synovial fluid. A prospective blinded study in patients with osteoarthritis of the knee. Osteoarthritis Cartilage. May. 2006;14(5):501-503. [pmid: 16431141].
78 Scott D, Kowalczyk A. Osteoarthritis of the knee. Clin Evid (Online). 2007;2007. [pmid: 19450299].
79 Shen X, Gatti R. The safety and efficacy of intra-articular dual molecular weighted hyaluronic Acid in the treatment of knee osteoarthritis: the Ide.h.a. Study. Orthop Rev (Pavia). 2013;5(4):e33. [pmid: 24416477].
80 Shimizu M, Higuchi H, Takagishi K, et al. Clinical and biochemical characteristics after intra-articular injection for the treatment of osteoarthritis of the knee: prospective randomized study of sodium hyaluronate and corticosteroid. J Orthop Sci. Jan. 2010;15(1):51-56. [pmid: 20151251].
81 Shoor S. Review: Viscosupplementation for knee osteoarthritis reduces pain and improves function. Evid Based Med. Feb. 2006;11(1):12. [pmid: 17213054].
82 Sofat N, Kuttapitiya A. Future directions for the management of pain in osteoarthritis. International Journal of Clinical Rheumatology. April. 2014;9(2):197-216. [pmid: 25018771].
83 Strand V, Conaghan PG, Lohmander LS, et al. An integrated analysis of five double-blind, randomized controlled trials evaluating the safety and efficacy of a hyaluronan product for intra-articular injection in osteoarthritis of the knee. Osteoarthritis Cartilage. Sep. 2006;14(9):859-866. [pmid: 16626978].
84 Sugimoto H, Yamada H, Terada N, et al. Intraarticular injection of high molecular weight hyaluronan for osteoarthritis of the knee -prediction of effectiveness with biological markers. J Rheumatol. Dec. 2006;33(12):2527. [pmid: 17143987].
85 Tang SF, Chen CP, Chen MJ, et al. Improvement of muscle strength in osteoarthritic knee patients after intraarticular knee injection of hyaluronan. Am J Phys Med Rehabil. Apr. 2005;84(4):274-247. [pmid: 15785260].
86 Tang SF, Chen CP, Chen MJ, et al. Changes in sagittal ground reaction forces after intra-articular hyaluronate injections for knee osteoarthritis. Arch Phys Med Rehabil. Jun. 2004;85(6):951-955. [pmid: 15179649].
87 Taruc-Uy RL, Lynch SA. Diagnosis and Treatment of Osteoarthritis. Primary Care -Clinics in Office Practice. December. 2013;40(4):821-836. [pmid: 24209720].
88 Toh EM, Prasad PS, Teanby D. Correlating the efficacy of knee viscosupplementation with osteoarthritic changes on roentgenological examination. Knee. Dec. 2002;9(4):321-330. [pmid: 12424042].
89 Towheed TE, Hochberg MC. A systematic review of randomized controlled trials of pharmacological therapy in osteoarthritis of the knee, with an emphasis on trial methodology. Semin Arthritis Rheum. Apr. 1997;26(5):755-770. [pmid: 9144851].
90 Tuncer T, Cay HF, Kacar C, et al. Evidence-based recommendations for the management of knee osteoarthritis: A consensus report of the Turkish league against rheumatism ORIGINAL (NON-ENGLISH) TITLE Diz osteoartrit tedavisinde kani{dotless}ta dayali{dotless} oneriler: Turkiye romatizma arasti{dotless}rma ve savas dernegi uzlasi{dotless} raporu. Turkish Journal of Rheumatology. 2012;27(1):1-17. 2012; FULL TEXT LINK http://dx.doi.org/10.5606/tjr.2012.001.
91 Van den Bekerom MP, Lamme B, Sermon A, et al. What is the evidence for viscosupplementation in the treatment of patients with hip osteoarthritis? Systematic review of the literature. Arch Orthop Trauma Surg. 2008;128:815-823. [pmid: 17874246].
92 van Tiel J, Reijman M, Bos PK, et al. Delayed gadolinium-enhanced MRI of cartilage (dGEMRIC) shows no change in cartilage structural composition after viscosupplementation in patients with early-stage knee osteoarthritis. PLoS One. 2013;8(11):e79785. [pmid: 24223194].
93 Vavken P, Dorotka R. A systematic review of conflicting meta-analyses in orthopaedic surgery. Clin Orthop Relat Res. Oct. 2009;467(10):2723-2735. [pmid: 19252958].
94 Vincent HK, Percival SS, Conrad BP, et al. Hyaluronic Acid (HA) Viscosupplementation on Synovial Fluid Inflammation in Knee Osteoarthritis: A Pilot Study. Open Orthop J. 2013;7:37884. [pmid: 24093052].
95 Wang CT, Lin J, Chang CJ, et al. Therapeutic effects of hyaluronic acid on osteoarthritis of the knee. A meta-analysis of randomized controlled trials. J Bone Joint Surg Am. Mar. 2004;86A(3):538-545. [pmid: 14996880].
96 Wang Y, Hall S, Hanna F, et al. Effects of Hylan G-F 20 supplementation on cartilage preservation detected by magnetic resonance imaging in osteoarthritis of the knee: a two-year single-blind clinical trial. BMC Musculoskelet Disord. 2011;12:195. [pmid: 21861935].
97 Wildi LM. Pharmacological therapy of arthrosis. Zeitschrift Fur Rheumatologie. Nov. 2013;72(9):885-894. PMID:WOS:000326645400010. [pmid: 24193191].
98 Wu JJ, Shih LY, Hsu HC, et al. The double-blind test of sodium hyaluronate (ARTZ) on osteoarthritis knee. Zhonghua Yi Xue Za Zhi (Taipei). Feb. 1997;59(2):99-106. [pmid: 9175299].
99 Wu MX, Li XH, Lin MN, et al. Clinical study on the treatment of knee osteoarthritis of Shen-Sui insufficiency syndrome type by electroacupuncture. Chin J Integr Med. Aug. 2010;16(4):291-297. [pmid: 20697938].
100 Yavuzer G, Sonel B, Suldur N, et al. Effects of intra-articular hylan G-F 20 injections on clinical and biomechanical characteristics of the knee in osteoarthritis. Int J Rehabil Res. Dec. 2005;28(4):371-374. [pmid: 16319566].
101 Zhang W. How to treat osteoarthritis: International consensus. International Journal of Rheumatic Diseases. September. 2013;16(SUPPL. 1):8.
102 Zhang W, Moskowitz RW, Nuki G, et al. OARSI recommendations for the management of hip and knee osteoarthritis, Part II: OARSI evidence-based, expert consensus guidelines. Osteoarthritis Cartilage. Feb. 2008;16(2):137-162. [pmid: 18279766].
103 Zychowicz ME. Viscosupplementation for knee osteoarthritis. J Am Assoc Nurse Pract. Mar. 2014;26(3):163-175. [pmid: 24574068].

## Mean age less than 65 years -N=78

1 Adams ME, Atkinson MH, Lussier AJ, et al. The role of viscosupplementation with hylan G-F 20 (Synvisc) in the treatment of osteoarthritis of the knee: a Canadian multicenter trial comparing hylan G-F 20 alone, hylan G-F 20 with non-steroidal anti-inflammatory drugs (NSAIDs) and NSAIDs alone. Osteoarthritis Cartilage. Dec. 1995;3(4):213-225. [pmid: 8689457].
2 Altman RD, Akermark C, Beaulieu AD, et al. Efficacy and safety of a single intra-articular injection of non-animal stabilized hyaluronic acid (NASHA) in patients with osteoarthritis of the knee. Osteoarthritis Cartilage. Aug. 2004;12(8):642-649. [pmid: 15262244].
3 Altman RD, Rosen JE, Bloch DA, et al. A double-blind, randomized, saline-controlled study of the efficacy and safety of EUFLEXXA for treatment of painful osteoarthritis of the knee, with an open-label safety extension (the FLEXX trial). Semin Arthritis Rheum. Aug. 2009;39(1):1-9. [pmid: 19539353].
4 Arden NK, Akermark C, Andersson M, et al. A randomized saline-controlled trial of NASHA hyaluronic acid for knee osteoarthritis. Curr Med Res Opin. Feb. 2014;30(2):279-286. [pmid: 24168077].
5 Baltzer AW, Moser C, Jansen SA, et al. Autologous conditioned serum (Orthokine) is an effective treatment for knee osteoarthritis. Osteoarthritis Cartilage. Feb. 2009;17(2):152-160. [pmid: 18674932].
6 Bayramoglu M, Karatas M, Cetin N, et al. Comparison of two different viscosupplements in knee osteoarthritis --a pilot study. Clin Rheumatol. May. 2003;22(2):118-122. [pmid: 12740676].
7 Bostan B, Sen U, Gunes T, et al. Comparison of intra-articular hyaluronic acid injections and mud-pack therapy in the treatment of knee osteoarthritis. Acta Orthop Traumatol Turc. 2010;44(1):42-47. [pmid: 20513990].
8 Bragatini A, Cassini M, de Bastiani G, et al. Controlled Single-blind trial of intra-articularly injected hyaluronic acid (Hyalgan) in osteoarthritis of the knee. Clin Trials J. 1987;24(4):333-340.
9 Brown DJ, Wood EV, Hannah HM, et al. Prospective comparison of sodium hyaluronate and hylan G-F 20 in a clinical practice: comment on the concise communication by Martens. Arthritis Rheum. May. 2004;50(5):1697-1698. author reply 8. [pmid: 15146447].
10 Bunyaratavej N, Chan KM, Subramanian N. Treatment of painful osteoarthritis of the knee with hyaluronic acid. Results of a multicenter Asian study. J Med Assoc Thai. Oct. 2001;84(Suppl 2):S576-S581. [pmid: 11853284].
11 Caborn D, Rush J, Lanzer W, et al. A randomized, single-blind comparison of the efficacy and tolerability of hylan G-F 20 and triamcinolone hexacetonide in patients with osteoarthritis of the knee. J Rheumatol. Feb. 2004;31(2):333-343. [pmid: 14760806].
12 Carrabba M, Paresce E, Angelini M, et al. The safety and efficacy of different dose schedules of hyaluronic acid in the treatment of painful osteoarthritis of the knee with joint effusion. European Journal of Rheumatology and Inflammation. 1995:25-31.
13 Chevalier X, Jerosch J, Goupille P, et al. Single, intra-articular treatment with 6 ml hylan G-F 20 in patients with symptomatic primary osteoarthritis of the knee: a randomised, multicentre, double-blind, placebo controlled trial. Ann Rheum Dis. Jan. 2010;69(1):113-119. [pmid: 19304567].
14 Clarke S, Lock V, Duddy J, et al. Intra-articular hylan G-F 20 (Synvisc) in the management of patellofemoral osteoarthritis of the knee (POAK). Knee. Jan. 2005;12(1):57-62. [pmid: 15664879].
15 Conrozier T, Jerosch J, Beks P, et al. Prospective, multi-centre, randomised evaluation of the safety and efficacy of five dosing regimens of viscosupplementation with hylan G-F 20 in patients with symptomatic tibio-femoral osteoarthritis: a pilot study. Arch Orthop Trauma Surg. Mar. 2009;129(3):417-423. [pmid: 18365224].
16 Corrado EM, Peluso GF, Gigliotti S, et al. The effects of intra-articular administration of hyaluronic acid on osteoarthritis of the knee: A clinical study with immunological and biochemical evaluations. European Journal of Rheumatology and Inflammation. 1995:47-56.
17 Creamer P, Sharif M, George E, et al. Intra-articular hyaluronic acid in osteoarthritis of the knee: an investigation into mechanisms of action. Osteoarthritis Cartilage. Jun. 1994;2(2):133-140. [pmid: 11548229].
18 Cubukcu D, Ardic F, Karabulut N, et al. Hylan G-F 20 efficacy on articular cartilage quality in patients with knee osteoarthritis: clinical and MRI assessment. Clin Rheumatol. Aug. 2005;24(4):336-341. [pmid: 15599642].
19 Day R, Brooks P, Conaghan PG, et al. A double blind, randomized, multicenter, parallel group study of the effectiveness and tolerance of intraarticular hyaluronan in osteoarthritis of the knee. J Rheumatol. Apr. 2004;31(4):775-782. [pmid: 15088306].
20 De Campos GC, De Rezende MU, Pailo AF, et al. Randomized prospective study evaluating addition of corticoid to viscosupplementation: Three months of follow-up. Revista Brasileira de Ortopedia. 2013;48(4):322-329.
21 de Campos GC, Rezende MU, Pailo AF, et al. Adding triamcinolone improves viscosupplementation: a randomized clinical trial. Clin Orthop Relat Res. Feb. 2013;471(2):61320. [pmid: 23100188].
22 Diracoglu D, Vural M, Baskent A, et al. The effect of viscosupplementation on neuromuscular control of the knee in patients with osteoarthritis. J Back Musculoskelet Rehabil. 2009;22(1):1-9. [pmid: 20023357].
23 Erturk C, Altay MA, Altay N, et al. Will a single periarticular lidocaine-corticosteroid injection improve the clinical efficacy of intraarticular hyaluronic acid treatment of symptomatic knee osteoarthritis?. Knee Surg Sports Traumatol Arthrosc. 2014. Nov. 2. [pmid: 25362247].
24 Filardo G, Kon E, Di Martino A, et al. Platelet-rich plasma vs hyaluronic acid to treat knee degenerative pathology: study design and preliminary results of a randomized controlled trial. BMC Musculoskelet Disord. 2012;13:229. [pmid: 23176112].
25 Frizziero L, Pasquali Ronchetti I. Intra-articular treatment of osteoarthritis of the knee: An arthroscopic and clinical comparison between sodium hyaluronate (500–730 kDa) and methylprednisolone acetate. Journal of Orthopaedics and Traumatology. Oct. 2002;3(2):89-96. FULL TEXT LINK http://dx.doi.org/10.1007/s101950200034.
26 Graf J, Neusel E, Schneider E, et al. Intra-articular treatment with hyaluronic acid in osteoarthritis of the knee joint: a controlled clinical trial versus mucopolysaccharide polysulfuric acid ester. Clin Exp Rheumatol. Jul-Aug. 1993;11(4):367-372. [pmid: 8403580].
27 Guler O, Mutlu S, Isyar M, et al. Comparison of short-term results of intraarticular platelet-rich plasma (PRP) and hyaluronic acid treatments in early-stage gonarthrosis patients. Eur J Orthop Surg Traumatol. 2014. Aug. 2. [pmid: 25085316].
28 Heisel J, Kipshoven C. Safety and Efficacy Findings from a Non-interventional Study of a New Hyaluronic Acid/Sorbitol Formulation (GO-ON(R) Matrix) for Intra-articular Injection to Relieve Pain and Disability in Osteoarthritis Patients. Drug Res (Stuttg). Sep. 2013;63(9):445-449. [pmid: 23599036].
29 Housman L, Arden N, Schnitzer TJ, et al. Intra-articular hylastan versus steroid for knee osteoarthritis. Knee Surg Sports Traumatol Arthrosc. 2013. Feb. 16. [pmid: 23417236].
30 Housman L, Arden N, Schnitzer TJ, et al. Intra-articular hylastan versus steroid for knee osteoarthritis. Knee Surg Sports Traumatol Arthrosc. Jul. 2014;22(7):1684-1692. [pmid: 23417236].
31 Iannitti T, Rottigni V, Palmieri B. A pilot study to compare two different hyaluronic acid compounds for treatment of knee osteoarthritis. Int J Immunopathol Pharmacol. Oct-Dec. 2012;25(4):1093-1098. [pmid: 23298499].
32 Jorgensen A, Stengaard-Pedersen K, Simonsen O, et al. Intra-articular hyaluronan is without clinical effect in knee osteoarthritis: a multicentre, randomised, placebo-controlled, double-blind study of 337 patients followed for 1 year. Ann Rheum Dis. Jun. 2010;69(6):1097-1102. [pmid: 20447955].
33 Jubb RW, Piva S, Beinat L, et al. A one-year, randomised, placebo (saline) controlled clinical trial of 500–730 kDa sodium hyaluronate (Hyalgan) on the radiological change in osteoarthritis of the knee. Int J Clin Pract. Jul-Aug. 2003;57(6):467-474. [pmid: 12918884].
34 Juni P, Reichenbach S, Trelle S, et al. Efficacy and safety of intraarticular hylan or hyaluronic acids for osteoarthritis of the knee: a randomized controlled trial. Arthritis Rheum. Nov. 2007;56(11):3610-3619. [pmid: 17968921].
35 Kalaci A, Yilmaz HR, Aslan B, et al. Effects of hyaluronan on nitric oxide levels and superoxide dismutase activities in synovial fluid in knee osteoarthritis. Clin Rheumatol. Aug. 2007;26(8):1306-1311. [pmid: 17180636].
36 Karatay S, Kiziltunc A, Yildirim K, et al. Effects of different hyaluronic acid products on synovial fluid levels of intercellular adhesion molecule-1 and vascular cell adhesion molecule-1 in knee osteoarthritis. Ann Clin Lab Sci. Summer. 2004;34(3):330-335. [pmid: 15487709].
37 Karatay S, Kiziltunc A, Yildirim K, et al. Effects of different hyaluronic acid productson synovial fluid NO levels in knee osteoarthritis. Clin Rheumatol. Sep. 2005;24(5):497-501. [pmid: 15906109].
38 Karatosun V, Unver B, Gocen Z, et al. Comparison of two hyaluronan drugs in patients with advanced osteoarthritis of the knee. A prospective, randomized, double-blind study with long term follow-up. Clin Exp Rheumatol. Mar-Apr. 2005;23(2):213-218. [pmid: 15895892].
39 Karatosun V, Unver B, Gocen Z, et al. Intra-articular hyaluranic acid compared with progressive knee exercises in osteoarthritis of the knee: a prospective randomized trial with long-term follow-up. Rheumatol Int. Feb. 2006;26(4):277-284. [pmid: 15776267].
40 Kirchner M, Marshall D. A double-blind randomized controlled trial comparing alternate forms of high molecular weight hyaluronan for the treatment of osteoarthritis of the knee. Osteoarthritis Cartilage. Feb. 2006;14(2):154-162. [pmid: 16242361].
41 Kon E, Mandelbaum B, Buda R, et al. Platelet-rich plasma intra-articular injection versus hyaluronic acid viscosupplementation as treatments for cartilage pathology: from early degeneration to osteoarthritis. Arthroscopy. Nov. 2011;27(11):1490-1501. [pmid: 21831567].
42 Kotevoglu N, Iyibozkurt PC, Hiz O, et al. A prospective randomised controlled clinical trial comparing the efficacy of different molecular weight hyaluronan solutions in the treatment of knee osteoarthritis. Rheumatol Int. Feb. 2006;26(4):325-330. [pmid: 15959784].
43 Kotz R, Kolarz G. Intra-articular hyaluronic acid: duration of effect and results of repeated treatment cycles. Am J Orthop (Belle Mead NJ). Nov. 1999;28(11 Suppl):5-7. [pmid: 10587245].
44 Kul-Panza E, Berker N. Is hyaluronate sodium effective in the management of knee osteoarthritis? A placebo-controlled double-blind study. Minerva Med. Apr. 2010;101(2):63-72. [pmid: 20467406].
45 Lee PB, Kim YC, Lim YJ, et al. Comparison between high and low molecular weight hyaluronates in knee osteoarthritis patients: open-label, randomized, multicentre clinical trial. J Int Med Res. Jan-Feb. 2006;34(1):77-87. [pmid: 16604827].
46 Leighton R, Akermark C, Therrien R, et al. NASHA hyaluronic acid vs. methylprednisolone for knee osteoarthritis: a prospective, multi-centre, randomized, non-inferiority trial. Osteoarthritis Cartilage. Jan. 2014;22(1):17-25. [pmid: 24185114].
47 Listrat V, Ayral X, Patarnello F, et al. Arthroscopic evaluation of potential structure modifying activity of hyaluronan (Hyalgan) in osteoarthritis of the knee. Osteoarthritis Cartilage. May. 1997;5(3):153-160. [pmid: 9219678].
48 Lohmander LS, Dalen N, Englund G, et al. Intra-articular hyaluronan injections in the treatment of osteoarthritis of the knee: a randomised, double blind, placebo controlled multicentre trial. Hyaluronan Multicentre Trial Group. Ann Rheum Dis. Jul. 1996;55(7):424-431. [pmid: 8774159].
49 Maheu E, Zaim M, Appelboom T, et al. Comparative efficacy and safety of two different molecular weight (MW) hyaluronans F60027 and Hylan G-F20 in symptomatic osteoarthritis of the knee (KOA). Results of a non inferiority, prospective, randomized, controlled trial. Clin Exp Rheumatol. May-Jun. 2011;29(3):527-535. [pmid: 21722501].
50 Maheu E, Zaim M, Appelboom T, et al. Comparative efficacy and safety of two different molecular weight (MW) hyaluronans F60027 and Hylan G-F20 in symptomatic osteoarthritis of the knee (KOA). Results of a non-inferiority, prospective, randomised, controlled trial. Clinical and Experimental Rheumatology. May-Jun. 2011;29(3):527-535. PMID:WOS:000293101500010. [pmid: 21722501].
51 Navarro-Sarabia F, Coronel P, Collantes E, et al. A 40-month multicentre, randomised placebo-controlled study to assess the efficacy and carry-over effect of repeated intra-articular injections of hyaluronic acid in knee osteoarthritis: the AMELIA project. Ann Rheum Dis. Nov. 2011;70(11):1957-1962. [pmid: 21852252].
52 Neustadt D, Caldwell J, Bell M, et al. Clinical effects of intraarticular injection of high molecular weight hyaluronan (Orthovisc) in osteoarthritis of the knee: a randomized, controlled, multicenter trial. J Rheumatol. Oct. 2005;32(10):1928-1936. [pmid: 16206349].
53 Ozturk C, Atamaz F, Hepguler S, et al. The safety and efficacy of intraarticular hyaluronan with/without corticosteroid in knee osteoarthritis: 1-year, single-blind, randomized study. Rheumatol Int. Feb. 2006;26(4):314-319. [pmid: 15703953].
54 Paker N, Tekdos D, Kesiktas N, et al. Comparison of the therapeutic efficacy of TENS versus intra-articular hyaluronic acid injection in patients with knee osteoarthritis: a prospective randomized study. Adv Ther. Mar-Apr. 2006;23(2):342-353. [pmid: 16751166].
55 Palmieri B, Rottigni V, Iannitti T. Preliminary study of highly cross-linked hyaluronic acid-based combination therapy for management of knee osteoarthritis-related pain. Drug Des Devel Ther. 2013;7:7-12. [pmid: 23326188].
56 Petrella RJ, Petrella M. A prospective, randomized, double-blind, placebo controlled study to evaluate the efficacy of intraarticular hyaluronic acid for osteoarthritis of the knee. J Rheumatol. May. 2006;33(5):951-956. [pmid: 16652426].
57 Puhl W, Bernau A, Greiling H, et al. Intra-articular sodium hyaluronate in osteoarthritis of the knee: a multicenter, double-blind study. Osteoarthritis Cartilage. Oct. 1993;1(4):233-241. [pmid: 15449510].
58 Raynauld JP, Torrance GW, Band PA, et al. A prospective, randomized, pragmatic, health outcomes trial evaluating the incorporation of hylan G-F 20 into the treatment paradigm for patients with knee osteoarthritis (Part 1 of 2): clinical results. Osteoarthritis Cartilage. Jul. 2002;10(7):506-517. [pmid: 12127830].
59 Rolf CG, Engstrom B, Ohrvik J, et al. A comparative study of the efficacy and safety of hyaluronan viscosupplements and placebo in patients with symptomatic and arthroscopy-verified cartilage pathology. Journal of Clinical Research. 2005:15-32.
60 Sanchez M, Fiz N, Azofra J, et al. A randomized clinical trial evaluating plasma rich in growth factors (PRGF-Endoret) versus hyaluronic acid in the short-term treatment of symptomatic knee osteoarthritis. Arthroscopy. Aug. 2012;28(8):1070-1078. [pmid: 22840987].
61 Say F, D GU, Yener K, et al. Platelet-rich plasma injection is more effective than hyaluronic acid in the treatment of knee osteoarthritis ORIGINAL (NON-ENGLISH) TITLE Injekce plazmy obohacene destickovym koncentratem je efektivnejsi nez kyselina hyaluronova vlecbe gonartrozy. Acta Chirurgiae Orthopaedicae et Traumatologiae Cechoslovaca. October. 2013;80(4):278-283. [pmid: 24119476].
62 Say F, Gurler D, Yener K, et al. Platelet-Rich Plasma Injection Is More Effective than Hyaluronic Acid in the Treatment of Knee Osteoarthritis. Acta Chir Orthop Traumatol Cech. 2013;80(4):278-283. [pmid: 24119476].
63 Scale D, Wobig LM, Wolpert W. Viscosupplementation of osteoarthritic knees with hylan: A treatment schedule study. Curr Ther Res Clin Exp. 1994:220-232.
64 Sezgin M, Demirel AC, Karaca C, et al. Does hyaluronan affect inflammatory cytokines in knee osteoarthritis?. Rheumatol Int. May. 2005;25(4):264-269. [pmid: 14999424].
65 Skwara A, Peterlein CD, Tibesku CO, et al. Changes of gait patterns and muscle activity after intraarticular treatment of patients with osteoarthritis of the knee: a prospective, randomised, doubleblind study. Knee. Dec. 2009;16(6):466-472. [pmid: 19362003].
66 Skwara A, Ponelis R, Tibesku CO, et al. Gait patterns after intraarticular treatment of patients with osteoarthritis of the knee--hyaluronan versus triamcinolone: a prospective, randomized, doubleblind, monocentric study. Eur J Med Res. Apr. 16. 2009;14(4):157-164. [pmid: 19380288].
67 Spakova T, Rosocha J, Lacko M, et al. Treatment of knee joint osteoarthritis with autologous platelet-rich plasma in comparison with hyaluronic acid. Am J Phys Med Rehabil. May. 2012;91(5):411-417. [pmid: 22513879].
68 Stitik TP, Blacksin MF, Stiskal DM, et al. Efficacy and safety of hyaluronan treatment in combination therapy with home exercise for knee osteoarthritis pain. Arch Phys Med Rehabil. Feb. 2007;88(2):135-141. [pmid: 17270509].
69 Strand V, Baraf HS, Lavin PT, et al. A multicenter, randomized controlled trial comparing a single intra-articular injection of Gel-200, a new cross-linked formulation of hyaluronic acid, to phosphate buffered saline for treatment of osteoarthritis of the knee. Osteoarthritis Cartilage. May. 2012;20(5):350-356. [pmid: 22342928].
70 Tascioglu F, Oner C. Efficacy of intra-articular sodium hyaluronate in the treatment of knee osteoarthritis. Clinical Rheumatology. May. 2003;22(2):112-117. MEDLINE PMID 12740675 (http://www.ncbi.nlm.nih.gov/pubmed/12740675) FULL TEXT LINK http://dx.doi.org/10.1007/s10067-002-0690-1. [pmid: 12740675].
71 Tasciotaoglu F, Oner C. Efficacy of intra-articular sodium hyaluronate in the treatment of knee osteoarthritis. Clin Rheumatol. May. 2003;22(2):112-117. [pmid: 12740675].
72 Tetik S, Ones K, Tetik C. Efficacy of intra-articular Hylan G-F 20 on osteoarthritis of the knee. The Pain Clinic. 2003:459-466.
73 Vad VB, Bhat AL, Sculco TP, et al. Management of knee osteoarthritis: knee lavage combined with hylan versus hylan alone. Arch Phys Med Rehabil. May. 2003;84(5):634-637. [pmid: 12736873].
74 Vaquerizo V, Plasencia MA, Arribas I, et al. Comparison of Intra-Articular Injections of Plasma Rich in Growth Factors (PRGF-Endoret) Versus Durolane Hyaluronic Acid in the Treatment of Patients With Symptomatic Osteoarthritis: A Randomized Controlled Trial. Arthroscopy. Oct. 2013;29(10):1635-1643. [pmid: 24075613].
75 Virupannavar S, Guggenheim C. A Patient with Fatal Necrotizing Fasciitis following the Use of Intra-Articular Sodium Hyaluronate Injections: A Case Report. Case Rep Med. 2013;2013:531794. [pmid: 24454403].
76 Wobig M, Bach G, Beks P, et al. The role of elastoviscosity in the efficacy of viscosupplementation for osteoarthritis of the knee: a comparison of hylan G-F 20 and a lower-molecular-weight hyaluronan. Clin Ther. Sep. 1999;21(9):1549-1562. [pmid: 10509850].
77 Wobig M, Dickhut A, Maier R, et al. Viscosupplementation with hylan G-F 20: a 26-week controlled trial of efficacy and safety in the osteoarthritic knee. Clin Ther. May-Jun. 1998;20(3):410-423. [pmid: 9663358].
78 Zoboli AA, de Rezende MU, de Campos GC, et al. Prospective randomized clinical trial: single and weekly viscosupplementation. Acta Ortop Bras. 2013;21(5):271-275. [pmid: 24453681].

## AEs where sample size was less than 500 -N=29

1 Allen E, Krohn K. Adverse reaction to Hylan GF-20. J Rheumatol. Jun. 2000;27(6):1572. [pmid: 10852302].
2 Altman RD, Rosen JE, Bloch DA, et al. Safety and efficacy of retreatment with a bioengineered hyaluronate for painful osteoarthritis of the knee: results of the open-label Extension Study of the FLEXX Trial. Osteoarthritis Cartilage. Oct. 2011;19(10):1169-1175. [pmid: 21820521].
3 Borregon-Nofuentes P, Aviles-Izquierdo JA, Martinez-Izquierdo MA, et al. Livedo reticularis and skin necrosis due to hyaluronic acid embolism. JAMA Dermatol. Mar. 2013;149(3):373-375. [pmid: 23553015].
4 Castellacci E, Polieri T. Antalgic effect and clinical tolerability of hyaluronic acid in patients with degenerative diseases of knee cartilage: an outpatient treatment survey. Drugs Exp Clin Res. 2004;30(2):67-73. [pmid: 15272644].
5 Chen AL, Desai P, Adler EM, et al. Granulomatous inflammation after Hylan G-F 20 viscosupplementation of the knee : a report of six cases. J Bone Joint Surg Am. Jul. 2002;84A(7):1142-1147. [pmid: 12107313].
6 Disla E, Infante R, Fahmy A, et al. Recurrent acute calcium pyrophosphate dihydrate arthritis following intraarticular hyaluronate injection. Arthritis Rheum. Jun. 1999;42(6):1302-1303. [pmid: 10366130].
7 Jones KB, Patel PP, DeYoung BR, et al. Viscosupplementation pseudotumor. A case report. J Bone Joint Surg Am. May. 2005;87(5):1113-1119. [pmid: 15866978].
8 Kolarz G, Kotz R, Hochmayer I. Long-term benefits and repeated treatment cycles of intra-articular sodium hyaluronate (Hyalgan) in patients with osteoarthritis of the knee. Semin Arthritis Rheum. Apr. 2003;32(5):310-319. [pmid: 12701041].
9 Kroesen S, Schmid W, Theiler R. Induction of an acute attack of calcium pyrophosphate dihydrate arthritis by intra-articular injection of hylan G-F 20 (Synvisc). Clin Rheumatol. 2000;19(2):147-149. [pmid: 10791628].
10 Lee S, Park D, Chmell SJ. Viscosupplementation with hylan G-F 20 (Synvisc): pain and mobility observations from 74 consecutive patients. J Knee Surg. Apr. 2004;17(2):73-77. [pmid: 15124659].
11 Leopold SS, Warme WJ, Pettis PD, et al. Increased frequency of acute local reaction to intra-articular hylan GF-20 (synvisc) in patients receiving more than one course of treatment. J Bone Joint Surg Am. Sep. 2002;84-A(9):1619-1623. [pmid: 12208919].
12 Lussier A, Cividino AA, McFarlane CA, et al. Viscosupplementation with hylan for the treatment of osteoarthritis: findings from clinical practice in Canada. J Rheumatol. Sep. 1996;23(9):1579-1585. [pmid: 8877928].
13 Luzar MJ, Altawil B. Pseudogout following intraarticular injection of sodium hyaluronate. Arthritis Rheum. May. 1998;41(5):939-940. [pmid: 9588748].
14 Monfort J, Lisbona MP, Gimenez-Arnau A, et al. Immunoallergic reaction following intraarticular injection of high molecular weight hyaluronic acid. Joint Bone Spine. October. 2013;80(5):541-555. FULL TEXT LINK http://dx.doi.org/10.1016/j.jbspin.2013.02.010. [pmid: 23731639].
15 Novaes AC, Schaiquevich P, Nasswetter G. Multicenter study of hyaluronic acid obtained by biotechnology to evaluate clinical efficacy and safety in knee osteoarthritis. Int J Clin Pharmacol Res. 2005;25(1):1-7. [pmid: 15864872].
16 Phiphobmongkol V, Sudhasaneya V. The effectiveness and safety of intra-articular injection of sodium hyaluronate (500–730 kDa) in the treatment of patients with painful knee osteoarthritis. J Med Assoc Thai. Oct. 2009;92(10):1287-1294. [pmid: 19845235].
17 Puttick MP, Wade JP, Chalmers A, et al. Acute local reactions after intraarticular hylan for osteoarthritis of the knee. J Rheumatol. Jul. 1995;22(7):1311-1314. [pmid: 7562764].
18 Rastogi S, Sharma VK, Chandra R, et al. Open label multicentre trial on safety and efficacy of intra-articular hyaluronic acid in the treatment of osteoarthritis of the knee -A prospective study. Journal, Indian Academy of Clinical Medicine. Jul. 2005;6(3):232-235.
19 Rat AC, Baumann C, Guillemin F. National, multicentre, prospective study of quality of life in patients with osteoarthritis of the knee treated with hylane G-F 20. Clin Rheumatol. Oct. 2011;30(10):1285-1293. [pmid: 21484226].
20 Sun SF, Hsu CW, Hwang CW, et al. Hyaluronate improves pain, physical function and balance in the geriatric osteoarthritic knee: a 6-month follow-up study using clinical tests. Osteoarthritis Cartilage. Jul. 2006;14(7):696-701. [pmid: 16520067].
21 Theiler R, Bruhlmann P. Overall tolerability and analgesic activity of intra-articular sodium hyaluronate in the treatment of knee osteoarthritis. Curr Med Res Opin. Nov. 2005;21(11):172733. [pmid: 16307692].
22 Ucar D, Diracoglu D, Suleyman T, et al. Intra-articular hyaluronic Acid as treatment in elderly and middle-aged patients with knee osteoarthritis. Open Rheumatol J. 2013;7:38-41. [pmid: 23919093].
23 Vincent HK, Montero C, Conrad BP, et al. "Functional pain," functional outcomes, and quality of life after hyaluronic acid intra-articular injection for knee osteoarthritis. PM R. Apr. 2013;5(4):310-318. [pmid: 23416148].
24 Waddell BS, Waddell WH, Waddell DD. Comparison of Efficacy and Tolerability of Hylan G-F 20 in Patients with and without Effusions at the Time of Initial Injection. J Knee Surg. 2014. May. 7. [pmid: 24807194].
25 Waddell DD, Beyer A, Thompson TL, et al. No conclusive evidence that histologically found granulomas and acute local reactions following hylan G-F 20 injections are related or have clinical significance. The journal of knee surgery. 2014;27(2):99-104. [pmid: 23873318].
26 Waddell DD, Cefalu CA, Bricker DC. An open-label study of a second course of hylan G-F 20 for the treatment of pain associated with knee osteoarthritis. Curr Med Res Opin. 2003;19(6):499-507. [pmid: 14594522].
27 Webber TA, Webber AE, Matzkin E. Rate of adverse reactions to more than 1 series of viscosupplementation. Orthopedics. Apr. 2012;35(4):e514-e519. [pmid: 22495852].
28 Yacyshyn EA, Matteson EL. Gout after intraarticular injection of hylan GF-20 (Synvisc) [5]. Journal of Rheumatology. 1999;26(12):2717. 1999; MEDLINE PMID 10606396 (http://www.ncbi.nlm.nih.gov/pubmed/10606396). [pmid: 10606396].
29 Zardawi IM, Chan I. Synvisc perisynovitis. Pathology. Nov. 2001;33(4):519-520. [pmid: 11827424].

## Duplicate data -N=7

1 Altman RD, Moskowitz R. A randomized clinical trial of intra-articular sodium hyaluronate in patients with osteoarthritis of the knee: a summary. Am J Orthop (Belle Mead NJ). Nov. 1999;28(11 Suppl):3-4. [pmid: 10587244].
2 Onel E, Kolsun K, Kauffman JI. Post-Hoc analysis of a head-to-head hyaluronic acid comparison in knee osteoarthritis using the 2004 OMERACT-OARSI responder criteria. Clin Drug Investig. 2008;28(1):37-45. [pmid: 18081359].
3 Raynauld JP, Goldsmith CH, Bellamy N, et al. Effectiveness and safety of repeat courses of hylan G-F 20 in patients with knee osteoarthritis. Osteoarthritis Cartilage. Feb. 2005;13(2):111-119. [pmid: 15694572].
4 Torrance GW, Raynauld JP, Walker V, et al. A prospective, randomized, pragmatic, health outcomes trial evaluating the incorporation of hylan G-F 20 into the treatment paradigm for patients with knee osteoarthritis (Part 2 of 2): economic results. Osteoarthritis Cartilage. Jul. 2002;10(7):518-527. [pmid: 12127831].
5 Waddell DD. Viscosupplementation with hyaluronans for osteoarthritis of the knee: clinical efficacy and economic implications. Drugs Aging. 2007;24(8):629-642. [pmid: 17702533].
6 Strand V, Baraf HSB, Lavin PT, et al. Effectiveness and Safety of a Multicenter Extension and Retreatment Trial of Gel-200 in Patients with Knee Osteoarthritis. Cartilage. October. 2012;3(4):297-304. FULL TEXT LINK http://dx.doi.org/10.1177/1947603512451024. [pmid: 26069640].
7 Sullivan KE, Mannery T, Petri MA. Pseudogout following intraarticular injection of sodium hyaluronate. Arthritis and Rheumatism. 1998;41(5):939-941. [pmid: 9588748].