# Search Strategy

DATABASE SEARCHED & TIME PERIOD COVERED:

PUBMED – 1/1/2014–12/11/2014

SEARCH STRATEGY:

(hyaluronic acid OR hyaluronate* OR hyaluronan OR hylan) AND (osteoarthritis, knee OR (knee* AND osteoarthritis) OR (knee* AND arthrit*) OR gonarthrosis)

OR

(hyaluronic acid OR hyaluronate* OR hyaluronan OR hylan) AND degenerative joint disease AND (knee OR knees)

OR

((viscosupplement* OR visco-supplement*) AND (osteoarthritis, knee OR (knee* AND osteoarthritis) OR (knee* AND arthrit*) OR gonarthrosis))

========================================================================

DATABASE SEARCHED & TIME PERIOD COVERED:

Web of Science Indexes=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH – 1/1/2014–12/11/2014

SEARCH STRATEGY:

TS=(hyaluronic acid OR hyaluronate* OR hyaluronan OR hylan) AND TS=(knee OR knees) AND TS=(osteoarthritis OR arthrit* OR gonarthrosis)

OR

TS=(hyaluronic acid OR hyaluronate* OR hyaluronan OR hylan) AND TS=(knee OR knees) AND TS=(degenerative joint disease)

OR

TS=(viscosupplement* OR visco-supplement*) AND TS=(knee OR knees) AND TS=(osteoarthritis OR arthrit* OR gonarthrosis)

========================================================================

DATABASE SEARCHED & TIME PERIOD COVERED:

SCOPUS – 1/1/2014–12/12/2014

SEARCH STRATEGY:

TITLE-ABS-KEY (hyaluronic acid OR hyaluronate* OR hyaluronan OR hylan) AND TITLE-ABS-KEY (knee OR knees)

OR

TITLE-ABS-KEY (hyaluronic acid OR hyaluronate* OR hyaluronan OR hylan) AND TITLE-ABS-KEY (knee OR knees) AND ALL ("degenerative joint disease")

OR

TITLE-ABS-KEY (viscosupplement* OR visco-supplement*) AND TITLE-ABS-KEY (knee OR knees) AND TITLE-ABS-KEY (osteoarthritis OR arthrit* OR gonarthrosis)

========================================================================

DATABASE SEARCHED & TIME PERIOD COVERED:

Cochrane – 1/1/2014–12/12/2014

SEARCH STRATEGY:

SEARCH 1:

hyaluronic acid or hyaluronate* or hyaluronan or hylan:ti,ab,kw (Word variations have been searched)

AND

osteoarthritis, knee or (knee* and osteoarthritis) or (knee* and arthrit*) or gonarthrosis

All Results (17)

Cochrane Reviews (0)

All Review Protocol

Other Reviews (2)

Trials (14)

Methods Studies (0)

Technology Assessments (0)

Economic Evaluations (1)

Cochrane Groups (0)

SEARCH 2:

hyaluronic acid or hyaluronate* or hyaluronan or hylan:ti,ab,kw (Word variations have been searched)

AND

degenerative joint disease

AND

knee or knees

All Results (2)

Cochrane Reviews (0)

All Review Protocol

Other Reviews (0)

Trials (2)

Methods Studies (0)

Technology Assessments (0)

Economic Evaluations (0)

Cochrane Groups (0)

SEARCH 3:

viscosupplement* or visco-supplement*:ti,ab,kw (Word variations have been searched)

AND

osteoarthritis, knee or (knee* and osteoarthritis) or (knee* and arthrit*) or gonarthrosis

All Results (5)

Cochrane Reviews (0)

All Review Protocol

Other Reviews (0)

Trials (4)

Methods Studies (0)

Technology Assessments (1)

Economic Evaluations (0)

Cochrane Groups (0)

========================================================================

DATABASE SEARCHED & TIME PERIOD COVERED:

Embase– 1/1/2014–12/12/2014

SEARCH STRATEGY:

SEARCH 1:

hyaluronic NEAR/2 acid* OR hyaluronate* OR 'hyaluronan' OR 'hyaluronan'/exp OR hyaluronan OR hylan AND

'osteoarthritis' OR 'osteoarthritis'/exp OR osteoarthritis AND ('knee' OR 'knee'/exp OR knee OR knees) OR (knee* AND arthrit*) OR 'gonarthrosis' OR 'gonarthrosis'/exp OR gonarthrosis

AND

Humans/lim

SEARCH 2:

hyaluronic NEAR/2 acid* OR hyaluronate* OR 'hyaluronan' OR 'hyaluronan'/exp OR hyaluronan OR hylan

AND

degenerative AND ('joint' OR 'joint'/exp OR joint) AND ('disease' OR 'disease'/exp OR disease)

AND

'knee' OR 'knee'/exp OR knee OR knees

AND

Humans/lim

SEARCH 3:

viscosupplement* OR 'visco supplement' OR 'visco supplements' OR 'visco supplemental'

AND

'osteoarthritis' OR 'osteoarthritis'/exp OR osteoarthritis OR arthrit* OR 'gonarthrosis' OR 'gonarthrosis'/exp OR gonarthrosis

AND

'knee' OR 'knee'/exp OR knee OR knees

AND

Humans/lim

==========================================================================

DATABASE SEARCHED & TIME PERIOD COVERED:

New York Academy of Medicine Grey Literature Report – 1/1/2014–12/12/2014

SEARCH STRATEGY:

Hyaluronic OR hyaluronate OR hyaluronan OR hylan OR viscosupplement OR visco-supplement

==========================================================================

DATABASE SEARCHED & TIME PERIOD COVERED:

Canadian Agency for Drugs and Technologies in Health (CADTH) – 1/1/2014–12/12/2014

SEARCH STRATEGY:

hyaluronic OR hyaluronate OR hyaluronan OR hylan OR viscosupplement OR visco-supplement

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 1/1/1990–10/30/2013

SEARCH STRATEGY:

(1a)

hyaluronic acid OR hyaluronate* OR hyaluronan OR hylan

AND

osteoarthritis, knee OR (knee* AND osteoarthritis) OR (knee* AND arthrit*) OR gonarthrosis

OR

(1b)

hyaluronic acid OR hyaluronate* OR hyaluronan OR hylan

AND

degenerative joint disease

AND

knee OR knees

OR

(1c)

viscosupplement* OR visco-supplement*

AND

osteoarthritis, knee OR (knee* AND osteoarthritis) OR (knee* AND arthrit*) OR gonarthrosis

====================================================================

DATABASE SEARCHED & TIME PERIOD COVERED:

Cochrane Databases – 1/1/1990–11/21/13

SEARCH STRATEGY 1a:

hyaluronic acid OR hyaluronate* OR hyaluronan OR hylan

AND

osteoarthritis, knee OR (knee* AND osteoarthritis) OR (knee* AND arthrit*) OR gonarthrosis

All Results (216)

Cochrane Reviews (5)

Other Reviews (14)

Trials (184)

Methods Studies (1)

Technology Assessments (7)

Economic Evaluations (5)

SEARCH STRATEGY 1b:

hyaluronic acid OR hyaluronate* OR hyaluronan OR hylan

AND

degenerative joint disease

AND

knee OR knees

All Results (8)

Cochrane Reviews (4)

Other Reviews (0)

Trials (4)

Methods Studies (0)

Technology Assessments (0)

Economic Evaluations (0)

SEARCH STRATEGY 1c:

viscosupplement* OR visco-supplement*

AND

osteoarthritis, knee OR (knee* AND osteoarthritis) OR (knee* AND arthrit*) OR gonarthrosis

All Results (57)

Cochrane Reviews (2)

Other Reviews (4)

Trials (45)

Methods Studies (0)

Technology Assessments (5)

Economic Evaluations (1)

=========================================================================

DATABASE SEARCHED & TIME PERIOD COVERED:

Embase – 1/1/1990–11/22/2013

SEARCH STRATEGY:

(1a)

hyaluronic NEAR/2 acid* OR hyaluronate* OR 'hyaluronan'/exp OR hyaluronan OR hylan

AND

osteoarthritis, AND ('knee'/exp OR knee) OR (knee* AND ('osteoarthritis'/exp OR osteoarthritis)) OR (knee* AND arthrit*) OR 'gonarthrosis'/exp OR gonarthrosis

AND

[humans]/lim

(EXCLUDE MEDLINE RESULTS)

(1b)

'degenerative joint disease'/exp OR 'degenerative joint disease' OR 'degenerative joint diseases'

AND

'knee'/exp OR knee OR knees

AND

[humans]/lim

(EXCLUDE MEDLINE RESULTS)

(1c)

viscosupplement* OR 'visco supplement' OR 'visco supplements' OR 'visco supplementation'

AND (knee* AND ('osteoarthritis'/exp OR osteoarthritis)) OR (knee* AND arthrit*) OR 'gonarthrosis'/exp OR gonarthrosis

AND

[humans]/lim

(EXCLUDE MEDLINE RESULTS)

==========================================================================

DATABASE SEARCHED & TIME PERIOD COVERED:

Web of Science Databases=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH – 1/1/1990–11/22/2013

SEARCH STRATEGY:

Topic=(hyaluronic acid OR hyaluronate* OR hyaluronan OR hylan) AND Topic=(knee OR knees) AND Topic=(osteoarthritis OR arthrit* OR gonarthrosis)

OR

Topic=(hyaluronic acid OR hyaluronate* OR hyaluronan OR hylan) AND Topic=(knee OR knees) AND Topic=(degenerative joint disease)

OR

Topic=(viscosupplement* OR visco-supplement*) AND Topic=(knee OR knees) AND Topic=(osteoarthritis OR arthrit* OR gonarthrosis)

==========================================================================

DATABASE SEARCHED & TIME PERIOD COVERED:

SCOPUS – 1/1/1990–11/25/2013

SEARCH STRATEGY:

(1a)

hyaluronic acid OR hyaluronate* OR hyaluronan OR hylan

AND

knee OR knees

AND

osteoarthritis OR arthrit* OR gonarthrosis

1481

(1b)

TITLE-ABS-KEY(hyaluronic acid OR hyaluronate* OR hyaluronan OR hylan)

AND

knee OR knees

AND

degenerative joint disease

AND

SUBJAREA(mult OR agri OR bioc OR immu OR neur OR phar OR mult OR medi OR nurs OR vete OR dent OR heal)

65

(1c)

TITLE-ABS-KEY((viscosupplement* OR visco-supplement*)

AND

knee OR knees

AND

osteoarthritis OR arthrit* OR gonarthrosis

AND

SUBJAREA(mult OR agri OR bioc OR immu OR neur OR phar OR mult OR medi OR nurs OR vete OR dent OR heal)

337

====================================================================

DATABASE SEARCHED & TIME PERIOD COVERED:

NEW YORK ACADEMY OF MEDICINE GREY LITERATURE REPORT – Earliest dates to 11/26/2013

SEARCH STRATEGY:

Hyaluronic OR hyaluronate OR hyaluronan OR hylan OR viscosupplement OR visco-supplement OR knee OR knees

====================================================================

DATABASE SEARCHED & TIME PERIOD COVERED:

CANADIAN AGENCY FOR DRUGS AND TECHNOLOGIES IN HEALTH (CADTH) GREY

MATTERS DATABASE – Earliest to 11/26/2013

SEARCH STRATEGY:

hyaluronic OR hyaluronate OR hyaluronan OR hylan

viscosupplement OR visco-supplement

knee OR knees