# Executive Summary

## Background

### Condition

Degenerative joint disease (usually termed osteoarthritis [OA]) of the knee is a condition characterized by the progressive destruction of the articular cartilage that lines the knee joints, the subchondral bone surfaces, and synovium, accompanied by pain, immobility, and reduction in function and the ability to complete activities of daily living (ADL).

In 2005, the estimated prevalence of osteoarthritis among adults in the United States (US), the number of individuals who had ever been told by a doctor that they had the condition, was approximately 27 million cases.1 Prevalence rates vary by the joint involved and the method of ascertainment (clinical vs. radiographic): symptomatically, the knee is the most frequently affected joint.2 The prevalence of osteoarthritis of the knee is increasing rapidly because of shifting population demographics: The primary risk factors for osteoarthritis of the knee are aging, obesity, prior injury, repetitive use,3 and female gender. The US Centers for Disease Control have estimated that the prevalence of symptomatic knee osteoarthritis may reach 50 percent by the age of 85.^4^ From 2002 to 2012, the number of individuals in the US with a total knee replacement (TKR) doubled from some 2 million to approximately 4 million).5 The increase in obesity has translated not only into an increase in incidence of osteoarthritis of the knee but also into a younger age of onset and need for treatment; as a result, by the time individuals with osteoarthritis of the knee reach the age of Medicare eligibility, the length of time they have had the condition has grown, their cases are more advanced,6 and the risk that surgery will be needed has increased. Thus, the aging of the baby boomer population, along with the increased incidence and prevalence of obesity have increased the risk for this condition, all representing an increasing strain on Medicare resources.

### Diagnostic Strategies

The clinical diagnosis of OA of the knee is typically based on presentation, including insidious onset of weight-bearing knee pain that is exacerbated by use of the joint and relieved by rest, and that tends to worsen over the course of the day. Radiographic evidence of OA may precede symptomatic OA but may not correlate with symptom severity. Radiologic severity can be estimated and expressed using the Kellgren and Lawrence criteria. However, a number of versions of the criteria exist: At low cutoff scores, correlation with symptoms is poor,7 whereas at higher cutoff scores, agreement tends to be higher. The primary impact of these different versions of the criteria may be the challenge that they create in trying to assess, compare, and pool the findings of research studies:7 Some longitudinal studies have even used different criteria at different time points within the same study. Because of the variation in scores for radiographic finding under various versions of the criteria (especially for individuals with less-advanced disease), stratification is important.

Some evidence suggests that among individuals with knee pain, MRI demonstrates physical signs of osteoarthritic changes in the knee before they are visible radiographically.8 However, the sensitivity and specificity of MRI in diagnosis and monitoring of progression have not yet been definitively demonstrated and is not used in routine clinical practice.

### Treatment Strategies

The goals of treatment for osteoarthritis of the knee include relief of pain and inflammation, slowing of progression, and improvement in or maintenance of mobility, function (including activities of daily living [ADLs]), and health-related quality of life (HRQoL).

Treatment options for OA of the knee include analgesics (e.g., acetaminophen) and anti-inflammatory agents (non-steroidal anti-inflammatory agents [NSAIDs], intraarticular corticosteroids), physical therapy and exercise (both to strengthen muscles that support the affected joints and to increase range of motion), weight loss, and if patients fail to obtain satisfactory relief from pain and improved function from the aforementioned treatments, partial or total arthroplasty (an alternative term for knee replacement) may be recommended for advanced cases. More recent therapies include intraarticular viscosupplementation, which involves local injections of the natural joint lubricant, hyaluronic acid, among other treatments.9

Hyaluronic acid (hyaluronate or hyaluronan) is a high molecular weight glycosaminoglycan synthesized in plasma membranes of connective tissues and secreted into the synovial fluid surrounding joints, where it forms part of the extracellular matrix.10 Intra-articular injection of HA was approved by the US Food and Drug Administration in 1997 as a medical device for the relief of pain due to osteoarthritis of the knee. Progressive osteoarthritis of the knee includes a decrease in, the concentration of hyaluronic acid by one half to two thirds of the normal value and a reduction the molecular size of the hyaluronic acid, lowering the viscoelastic properties of the synovial fluid.11 Injecting hyaluronic acid intraarticularly was posited as a means to restore the viscosity of the synovial fluid; thus approval was sought for HA as a device rather than as a drug12 (the distinction being that a device does not exert its effect via a chemical interaction with the body. A large number of trials have examined the efficacy and safety of supplemental hyaluronic acid injections, usually to relieve pain, but sometimes also to improve function in patients with OA of the knee, with varying efficacy results. Systematic reviews have attempted to resolve these conflicting findings. Some reviews have reported positive outcomes13,14 whereas some have reported mixed effects.12,15–17 A 2010 update of an earlier systematic review actually found a decrease in the effect size for hyaluronic acid on knee osteoarthritis from the previous review.18 The discrepancies in outcomes are likely due to study heterogeneity both within and among reviews with respect to population characteristics, intervention modalities, treatment and followup duration, and the actual outcomes measured (e.g., pain, functionality, HRQoL), as well as the measures employed. Heterogeneity may also be attributable to how efficacy is expressed, i.e., the proportion of each treatment group that responds positively to treatment, vs. the mean change in that efficacy measure from baseline in the active treatment group vs. the comparison group, and whether participants are credibly blinded to treatment allocation (using an intraarticular placebo control). Table 1 in the main text describes the HA products currently approved for use in the US.

In the 2012 update to their 2000 guidelines for the treatment of osteoarthritis of the knee, hip, and hand, the American College of Rheumatology conditionally recommended hyaluronic acid injections for patients who had an inadequate response to initial therapy.9 The 2013 American Academy of Orthopedic Surgeons guidelines for the treatment of osteoarthritis of the knee recommend against the use of hyaluronic acid to treat patients with symptomatic conditions.19

#### Assessment of Outcomes of Treatment

A number of assessment tools are used to assess pain, quality of life, and physical functioning in patients with osteoarthritis of the knee. These tools can be divided into those specifically developed for knee osteoarthritis and those that are used for a variety of conditions.

Tools specifically developed and validated to assess pain and functioning associated with osteoarthritis of the knee as well as treatment outcomes include the Western Ontario-McMaster Universities Arthritis Index (WOMAC20), the Lequesne Index21, the Knee Injury and Osteoarthritis Outcomes Score (KOOS22), and the Animated Activity Questionnaire.23 In 2004, the Osteoarthritis Research Society International (OARSI) developed a consensus set of guidelines to assess the outcomes of research trials on products intended to treat osteoarthritis; and under the International League of Rheumatologists, OMERACT (Outcome Measures in Rheumatology) has developed guidelines on outcome measures.24

General tools that have been adapted for use in assessing osteoarthritis of the knee include the Short form (SF)-36, developed at RAND for the Medical Outcomes Study25 and the Activities of Daily Living (ADLs) and IADLs assessment.

The Kinemax Outcomes Group has used a combination of the WOMAC, the SF-36, and a series of questions addressing demographic characteristics to predict patient outcomes of total knee arthroplasty.26

### Scope and Key Questions

The scope of work for this task order includes an assessment of the evidence that intraarticular HA injections prevent or delay the need for TKR among individuals 65 and over and that they improve function and quality of life. The Centers for Medicaid and Medicare Services (CMS) currently covers HA injections for elderly Medicare recipients under certain conditions.27 If HA is effective, it is postulated that it might effectively prevent or delay the need for life-disrupting surgery and rehabilitation by relieving pain and improving function with minimal inconvenience or adverse effects; however, if the treatment delays arthroplasty but fails to halt progressive degeneration, patients could potentially experience worse outcomes, although thus far, evidence for such outcomes has been weak. In addition to assessing the evidence for a role of HA in delaying or preventing the need for TKR, and assessing the evidence to date on the efficacy of intra-articular injections of HA with respect to the outcomes of function, ADLs/IADS, and quality of life, the report aims to assess the evidence to date on the safety of intraarticular HA when used as indicated and to scan the literature on the evidence for a role of HA in controlling pain. The key questions were provided by the CMS Coverage Analysis Group. They are presented here along with a description of the participants, interventions, comparators, outcomes, and timeframes (PICOTs) of interest, which defined the inclusion and exclusion criteria of the review. An analytic framework that shows the interrelationships among the presenting problems, the interventions and the outcomes of interest appears below.

Key question 1. Does intra-articular injection of hyaluronic acid eliminate the need for knee replacement surgery? Is this outcome affected by the type of hyaluronic acid, the type of presentation, severity at study entry, or age at study entry?

Key Question 2. Does intra-articular injection of hyaluronic acid significantly postpone the need for knee replacement surgery?

Key Question 3. Does intra-articular injection of hyaluronic acid improve the ability to successfully perform activities of daily living (ADLs) or instrumental activities of daily living (IADLs)?

Key Question 4. Does intra-articular injection of hyaluronic acid improve quality of life? PICOTs for KQ1 through 4 are the same with the exception of outcomes.

The effects of hyaluronic acid injection on pain and adverse events associated with hyaluronic acid injection were not included in the key questions posed by CMS. However because pain is regarded as an important component of effectiveness for treatments for OA of the knee and because safety is also an important treatment consideration, we volunteered to appraise this literature.

## Methods

### Criteria for Inclusion/Exclusion of Studies in the Review

We sought randomized placebo-controlled trials, head-to-head trials, or quasi-randomized trials that reported results for individuals whose average age was 65 or older; that assessed the effects of intra-articular HA on function, quality of life, delay of TKR, and prevention of the need for TKR (as well as factors that might affect these outcomes, such as age, disease severity, or comorbidities); and were powered to see a clinically important difference. If no randomized controlled trials (RCTs) were identified that assessed an outcome of interest, we included observational studies that assessed the outcome in question. Studies were included that enrolled individuals with other comorbidities and that enrolled community dwelling or institutionalized participants. Acceptable comparators included placebo (sham injection) or other HA devices. Studies with followup times of 4 weeks or longer were accepted. Adverse effects were assessed in randomized placebo-controlled trials, case reports, and large observational studies. Although it was outside the original scope, we also assessed the effects of HA on pain because it is the sole treatment indication for which HA is approved and is the most frequently reported primary outcome in trials of intraarticular HA injection; for this outcome, we identified several recent, comprehensive, good to high quality systematic reviews as well as randomized placebo-controlled trials published after the reviews.

Figure A Analytic framework of the effects of hyaluronic acid (HA) (vs. placebo or active comparator) on function, pain, adverse events, and delay/avoidance of total knee replacement

Figure notes: The framework shows potential outcomes of treatment with intraarticular HA (and placebo) the review sought to assess. These outcomes include a change in function, ADLs/IADLs (KQ3), a change in overall quality of life (KQ4), a change in pain, possible adverse events, and perhaps ultimately, a delay in TKR or decision not to undergo TKR, based potentially in part on some effect of treatment on pain, function, or quality of life.

ADL: Activities of Daily Living; DJD=Degenerative Joint Disease; HA=Hyaluronic Acid; IADLs=Instrumental Activities of Daily Living

Figure A. Analytic framework of the effects of hyaluronic acid (HA) (vs. placebo or active comparator) on function, pain, adverse events, and delay/avoidance of total knee replacement (arthroplasty) This figure depicts the key questions within the context of the PICOTS described in the previous section. In general, the figure illustrates the possibilities that compared with placebo and alternate treatments, hyaluronic acid (HA) could prevent the need for surgery (KQ1), delay surgery (KQ2), affect activities of daily living (ADLs) or instrumental activities of daily living (IADLs) (KQ3), or affect quality of life (KQ4). The figure also shows that we will assess whether the treatment, compared with placebo and alternate treatments, may result in adverse events, to which delayed surgery could potentially contribute.

### Literature Search Strategy

The search strategy was based in part on a search conducted for a 2012 evidence review on HA,16 with the addition of search terms for the additional outcomes of interest: arthroplasty/total knee replacement, functional outcomes (e.g., WOMAC, Lequesne Index), ADLs, IADLs (including terms for the tools commonly used to assess ADLs and IADLs, e.g., Lawton IADL scale, Katz Index), and quality of life (Appendix A of the full report).

PubMed, CINAHL, EMBASE, Web of Science, SCOPUS, and Cochrane were searched from 1990 to the present to identify original studies of HA. To capture unpublished or not-yet-published findings, we searched the New York Academy of Medicine database of grey literature, the database Grey Matter, a grey literature tool from the Canadian Agency for Drugs and Technologies in Health; clinicaltrials.gov; and the FDA Premarket Approval (PMA) database. The AHRQ Scientific Resource Center contacted the manufacturers of HA devices approved for use in the US to obtain scientific information packets (SIPs) on their products. Systematic reviews that reported on outcomes of interest were identified by searching the Cochrane Database, and original studies were obtained if not already identified among the results of the searches. Non-US studies were included if the intervention on which they reported was approved in the US for the indicated use, or if it was similar to a device approved for use in the US. Non-English language studies were not included; however we surveyed a random sample of the abstracts of non-English language studies to assess whether these studies differed in any apparently systematic way from English-language studies (the results are presented in Appendix E of the full report).

The titles and abstracts obtained from the literature searches were independently screened by two reviewers after being input into the systematic review database, DistillerSR; all selected articles were obtained. A second round of screening was then conducted with full text to exclude articles that provided no usable data on the outcomes of interest; reported duplicate data; were observational in design and reported only on adverse events and enrolled fewer than 500 participants; enrolled a population whose mean age was less than 65 years (unless the study outcomes were reported by age group and we could abstract outcomes for older individuals); or reported no outcomes of interest. When conference abstracts of interest were identified, we sought peer reviewed articles that reported the same data.

An update search was conducted on December 12, 2014, dating back to 6 months prior to the initial searches, while the draft report underwent peer review. Any new articles identified by the update search or suggested by peer reviewers were screened using the methods applied initially.

### Data Abstraction, Management, and Synthesis

Study-level details and outcome data were dually abstracted in DistillerSR. Disagreements were reconciled with the input of the principal investigator. Data that were collected fell into two categories: PICOTs (study-level data) and outcomes (study findings). Study-level data included the population demographics (age, sex, weight status), fitness level (if reported), comorbidities, disease stage, methods of ascertainment, intervention protocols, comparators, outcomes assessed in the study, and time course of interventions.

Data were abstracted for the following outcomes, when reported: receipt of TKR, time elapsed between HA therapy and TKR, change in functional status (as measured using the WOMAC, Lequesne, or KOOS scales), range of motion, ADLs/IADLs, QoL/Health-related QoL, adverse events, (and for studies reporting on pain and published subsequent to the two most recent systematic reviews, pain).

If three or more studies were determined to be relatively homogeneous with respect to intervention, outcome, and follow-up times, we conducted a meta-analysis, estimating a pooled random-effects estimate of the overall effect size using the Hartung-Knapp-Sidik-Jonkman method for our random effects meta-analysis.28 This method has been preferred when the number of pooled studies is small. It has been shown that the error rates are more acceptable than the previously used DerSimonian and Laird method.29

To obtain an estimate of the clinical importance of the pooled effect size for function (which represented a standardized mean difference), we compared it to the minimum clinically important difference (MCID) derived for large groups of patients with OA of the knee undergoing similar treatments and used in one of the two most recent comprehensive systematic reviews and the minimum clinically important improvement (MCII) used in the other recent review and recommended by OMERACT-OARSI, as well as MCII derived by Tubach and colleagues and used in a recent trial included in the report.16,30–34

In addition to obtaining the standardized effect size for each trial, we attempted to abstract the proportion of participants who reported improvement in function; a subset of studies reported on global improvement only.

The RCTs that compared active treatments head to head were not pooled, as the numbers of studies comparing the same interventions were insufficient. Similarly, the numbers of studies that reported on ADLs or quality of life were insufficient to allow pooling. The results are reported narratively. RCTs reporting on total knee replacement/arthroplasty were also small in number and are described narratively. Because only three RCTs reported on arthroplasty (and only one considered it as a treatment outcome), we included observational studies that assessed arthroplasty. The results of these studies are described narratively.

Publication bias was assessed for all pooled outcomes using the Begg adjusted rank correlation test35 and Egger regression asymmetry test.36 Heterogeneity was assessed using the I^2^ test.37 An effect-size or odds ratio was calculated for trials that reported data but did not contribute to a pooled analysis, and these studies were described narratively. All efficacy analyses were conducted with Stata statistical software, version 12.0 (Stata Corp., College Station, Texas).

Because we identified several large, recent, comprehensive systematic reviews on the outcome of pain, we selected the two most recent (and comprehensive) and described the results of these reviews as well as those of newer original trials that were not included in a prior meta-analysis.

### Risk of Bias (Quality) Assessment of Individual Studies

Individual study quality/risk of bias (ROB) for randomized trials was assessed using a set of questions adapted from the Cochrane Risk of Bias Assessment Tool38 and the EPC Methods Handbook (chapter 5).39 The quality of observational studies included for assessment of efficacy was assessed using a modification of the Newcastle-Ottawa Scale.40 The quality of RCTs included in the assessment of adverse events was assessed using the McHarms tool.41 The quality of systematic reviews was assessed using the AMSTAR tool.42

### Strength of the Body of Evidence

The strength of evidence was assessed for each conclusion within each key question using the EPC modification of the GRADE system (Table A).43 The domains are defined in Appendix G of the full report.44

### Applicability

The applicability of the findings was assessed based on age, study setting, and study design.

## Results

We describe first the results of the literature searches, followed by the findings for effects of HA treatment on TKR, function, quality of life, pain, and adverse events.

### Results of Literature Searches

The searches of peer reviewed literature identified 2,461 unique titles. The partner, CMS, provided 84 titles, of which all but 9 were already included in the search results. Reference mining of those studies yielded an additional 10 titles. The searches of grey literature yielded 48 titles. Information provided by manufacturers (Scientific Information Packets (SIPs)) included two titles, of which two unique titles were accepted. Altogether, 2,528 titles and abstracts went on to dual screening.

Of the 2,528 titles, 512 were initially identified for full-text review. The remaining 2,016 titles and abstracts were rejected for being animal or in vitro studies (405), not reporting on OA of the knee (324), not using intra-articular HA injections (417), not reporting any outcomes of interest (170), having an inappropriate study design (e.g., obvious commentaries or non-systematic reviews) (407), not enrolling a population of interest (30), or being written in a non-English language (258). Three articles could not be obtained and two had duplicate data.

A second level of screening was conducted on the 512 titles and abstracts initially identified for full-text review. Of the 512 titles, 366 were rejected: Studies were rejected at this stage for the following reasons: language not English (8), study design (124); participants excluded (10); interventions not of interest (7); outcomes not of interest (103); mean age less than 65 (78); adverse event (AE) reports with sample size less than 500 (29); or duplicate data (7). Of the remaining 83 studies, two systematic reviews were accepted, 81 were background articles, and 63 were original studies that underwent detailed abstraction. These included RCTs that reported function, ADLs/IDLs, QoL, TKR, and/or AEs (25); case series or prospective cohort studies reporting AEs or TKR (20); or case reports reporting AEs (18). Of the case series and cohort studies that reported AEs, only those that enrolled populations of 500 or greater were included, to ensure detection of rare AEs.

Figure B Literature Flow Diagram

Footnotes: ADLs=Activities of Daily Living; IADLs=Instrumental Activities of Daily Living AEs=Adverse events; CMS=Center for Medicaid Services; SIPs: Scientific Information Packets

Figure B. Literature Flow Diagram Figure B is the flow chart that summarizes the study retrieval and selection process for articles. The information displayed in the figure is described in the section entitled Results of Literature Searches.

Table A Strength of Evidence

Outcome | Strength of evidence Grade | Study Design | No. Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Other Issues | Finding
Arthroplasty | Insufficient | RCTs | 3 13 | High | Direct | Consistent | Imprecise | Suspected | TKR not intended outcome in 2 trials | No pooled effect size
Arthroplasty | Insufficient | Observational | 3 13 | High | Direct | Consistent | Imprecise | Suspected | TKR not intended outcome in 2 trials | No pooled effect size
Function: HAs vs. placebo | Low | RCTs | 10 | Moderate | Direct | Inconsistent | Precise | None | 2ndary outcome | −0.23 (−0.34, 0.02)
Function: HA vs. HA | Insufficient | RCTs | 5 | High | Direct | Inconsistent | Imprecise | unknown | 2ndary outcome | No pooled effect size
Quality of Life | Insufficient | RCTs | 2^*^ 1 | High | n/a | n/a | n/a | n/a | Different outcome measures | No pooled effect size
Adverse Events: total | Moderate | RCTs Observational cohort case reports | 25 4 18 | Moderate | Direct | Consistent | Precise | Unknown | Cohort studies included patients <65 | Similar rates of AEs were reported in studies of HA and placebo
Adverse Events: serious (SAEs) | Moderate for the rarity of SAEs; Low for a difference between the intervention and placebo groups | RCTs | 25 | Moderate | Direct | Consistent | Imprecise | Unknown | Causal mechanism not proposed for some SAEs | Joint: 0.77(0.25, 2.31) Other: 0.62(0.23, 1.57)

* Two trials compared Synvisc® to Hyalgan;® one trial compared Hyalgan® to saline. Each used a different measure

#### Delay or avoidance of total knee replacement surgery

Three RCTs45–47 and 13 observational studies (reported in 16 articles)48–63 reported on total knee replacement (TKR) after administration of intra-articular HA injections. Of the three RCTs, only one assessed TKR as a prespecified outcome of interest: They reported it as a treatment failure.

##### Key Points

- Three RCTs enrolled small numbers of patients and reported on TKR: Two did not specify TKR as a prespecified outcome of interest but as a treatment failure, whereas the third reported it as the primary outcome. One study reported higher rates of TKR among HA-treated patients, whereas the other two reported higher rates among placebo-treated patients.
- Six case series and seven cohort studies reported on TKR as an outcome following HA treatment. Most studies reported delays in, or lower rates of, TKR with HA injections compared with the usual progression or the rate seen in an untreated cohort. Two studies that assessed risk factors for undergoing TKR over a 12 year follow-up among those treated with HA found that only baseline severity and age were factors: those in the 60 to 69-year old age range in one study and in the 65 to 79-year range in the other were significantly more likely than those younger or older to undergo TKR, and in the former study, the time from diagnosis to TKR was faster for the 60–69 year old age group. No study reported the criteria used by the treating physicians for recommending patients to undergo knee replacement surgery (although all patients enrolled in the largest and longest cohort study had Kellgren-Lawrence Stage IV OA and were considered candidates for TKR by the treating physicians) or the characteristics that distinguished those who underwent surgery.

#### Intra-articular injection of hyaluronic acid and measures of function

We identified 18 randomized trials that compared the effects of HA with another HA64–69 or sham (intraarticular) placebo control45,47,66,70–76 or both using a validated measure of function, including the WOMAC, Lequesne, ADLs, or IADLs, in individuals with OA of the knee whose average age was 65 or older. Two studies compared an HA to other active treatment.46,77

##### Key Points

- Our meta-analysis of 10 studies that compared the effect of an HA to that of a sham placebo control showed a statistically significant improvement in WOMAC-assessed function following HA treatment, compared to placebo (standardized effect size or standardized mean difference [SMD] −0.23, 95% CI −0.34, −0.02) that did not achieve the MCID of −0.37 applied in a systematic review by Rutjes and colleagues16 but did exceed the MCII of −0.12 derived by Tubach and colleagues, as well as the MCII of −0.20 used in a recent network meta-analysis by Bannuru and colleagues30 (based on the OMERACT-OARSI responder criteria); based on the pooled effect size, about 11 percent would have exceeded the MCID of 0.37 in improvement and about 33 percent would have exceeded the MCII of −0.12) at follow-up.45, 47, 66, 70–76
- The number of head-to-head trials is too small to be able to assess the relative superiority of one HA over another.
- One head-to-head study found that 69% of patients given an intermediate-weight HA and 56% of patients given a lower-molecular weight HA achieved the pre-specified MCII for function. Seven studies assessed the proportion of patients with patient- or investigator reported global improvement; of the four that were placebo-controlled, three reported significant increases in the proportion of HA-treated patients who improved, compared with the proportion of placebo-treated patients who improved.
- No studies assessed the effect of HA on range of motion.
- No studies assessed the durability of effect.

#### Intra-articular injection of hyaluronic acid and quality of life

Three randomized trials were identified that assessed quality of life. A 2008 saline-controlled randomized trial assessed quality of life using the KOOS quality-of-life component.74 Two head-to-head trials that compared Genzyme Synvisc® with FIDIA Hyalgan® also assessed quality of life/health-related quality of life (HRQoL), one using the SF-36 mental component summary,67 and one using the EuroQol-5D index (for HRQoL).69

##### Key Points

- Three trials that compared HA to saline or to another HA found no differences in quality of life between the two groups at 6 months follow-up.

#### Intra-articular injection of hyaluronic acid and pain

Pain is the most frequently assessed outcome for HA but was not within the scope of the present review. However, the studies that have assessed the effect of intraarticular HA on pain have been assessed in numerous recent systematic reviews with meta-analysis. We summarized the findings of two of the most recent, comprehensive, and good to high quality meta-analyses. One good quality 2012 review summarized the entire body of trials that compared the effects of HA with those of a sham or nonintervention control on pain; this review also included separate analysis for double-blind placebo control trials and stratified analyses for a number of potential effect modifiers.15,16,78–81 A 2015 network meta-analysis compared the effects of pharmacological treatments (oral and intraarticular) for knee OA, intraarticular HA, and oral and intraarticular placebos for the treatment of knee OA.30

We identified no double-blind placebo controlled randomized trials that reported the effects of HA on pain and enrolled only individuals 65 and over, and no such studies in individuals of average age 65 and over that were published subsequent to these systematic reviews. We did identify and reviewed the results of two recent randomized head-to-head trials not included in the previous reviews that assessed the effects of HA on pain in individuals of average age 65 and over.64,67

##### Key Points

- A large, comprehensive 2012 systematic review of RCTs that assessed the effects of HA on pain in 71 RCTs (with either sham or non-sham controls) reported that HA injections significantly reduce pain when assessed at 3 months (−0.37, 95% CI −0.46, −0.28) and the effect met the criterion for a MCID (−0.37, which corresponded to 9mm on a VAS scale of 0 to 100mm); When the reviewers performed a subgroup analysis that included only the 18 sham-controlled, assessor-blinded studies with sample size of 100 or more per intervention group in the pooled analysis, the effect of HA was still statistically significant (−0.11, 95% CI −0.18, −0.04), but no longer met the criterion of clinical importance. A stratified analysis comparing the effect size for all 54 studies with a sham control (regardless of size) with that of the 18 studies with a non-sham comparison obtained a pooled effect size for the sham-controlled studies of −0.34 (95% CI −0.44, −0.24), nearly equal to that for the entire group of studies and to the MCID.
- A 2015 network meta-analysis of 129 RCTs that compared the effects of oral and intraarticular pharmacologic agents, HA, and placebo on pain (52 studies compared HA with placebo and 12 compared HA with steroids) reported a significant effect size of HA compared with placebo (−0.34; 95% CI −0.42, −0.26), exceeding the prespecified absolute MCII of −0.20, based on the OMERACT-OARSI responder criteria; sensitivity analysis showed that limiting study size to 50 or more did not change the effect size, but limiting the analysis to studies of 100 or more did reduce the effect size.
- No new placebo-controlled trials were identified that were not already included in the comprehensive 2012 systematic review on the effects of HA or that of Bannuru and colleagues, enrolled patients of average age 65 and older, and reported on pain outcomes.
- Two new head-to-head trials compared the effects of two different HAs on pain in individuals of average age 65 and over and were not included in prior SRs. One found that single injections of a high- and low-molecular weight were equally effective in reducing pain and improving function at 6 months (with no change in quality of life), whereas another found that three injections of an intermediate molecular weight HA might be superior to low molecular weight HA over 6 months (with respect to reducing pain and improving function). The latter study found that 70.5% of participants receiving the intermediate molecular weight product and 58.4% of participants receiving the lower molecular weight product exceeded the prespecified MCII for pain.

#### Intra-articular injection of hyaluronic acid and adverse events

Twenty four trials45–47,64–77,82–89, four large cohort and case series studies,90–93 and 18 case reports94–111 were identified that reported on the incidence of adverse events among individuals 65 years of age and over.

##### Key Points

- In 24 placebo-controlled trials of HA, serious adverse events were small in number.
- Among four large cohort studies and case series, representing nearly 6,000 recipients of HA (some more than one series), one serious adverse event was reported: severe swelling and synovial fluid accumulation.
- Eighteen case reports provided reports of adverse events among 30 individuals 65 years of age or older, including five cases of sepsis (one case of staphylococcus scalded skin syndrome), and one case each of saphenous nerve injury, eosinophiluria, erythema, and herpes zoster (new onset).

## Discussion

### Key Findings and Strength of Evidence

#### Intra-articular HA and TKR

Three randomized trials and 13 observational studies reported on TKR. Two of the trials did not regard receipt of TTKR as a prespecified outcome of interest, one of the two enrolled patients whose average was under 65, and none of the trials were adequately powered to compare the rates of TKR between HA and comparison groups. A number of observational studies reported rates of TKR among HA recipients; one study that followed over 1000 patients for as long as 12 years reported an overall incidence of TKR of 25% and an average delay of 2.8 years (compared with 3 months for a cohort that chose not to be treated). However, observational studies cannot control for the selection effect whereby patients who are more or less inclined to TKR are selected by their physicians for getting—or not getting—HA injections. Therefore, without randomized trials designed and adequately powered to assess the effect of HA on TKR, it is not possible to draw conclusions at this time regarding the effect of HA treatment on delay or avoidance of TKR.

The strength of evidence for this question is insufficient to draw any conclusions about the effect of HA on TKR.

#### Intra-articular HA and Function

Pooling of ten placebo-controlled studies that reported outcomes for the WOMAC or Lequesne revealed a small but significant increase in function in favor of HA (−0.23, 95% CI −0.34, −0.02); seven of the ten measured outcomes at 6 months. This difference did not achieve the MCID of −0.37 applied by Rutjes and colleagues but did exceed the MCII of −0.20 recommended by the OMERACT-OARSI guidelines (and applied by Bannuru and colleagues) and the MCII of −0.12 derived by Tubach and colleagues. Two studies reported no difference between HA and placebo. Based on the pooled effect size, approximately 11 percent of patients would have exceeded the MCII in improvement.

One trial reported on the effects of HA on ADLs. This study found no change from baseline in the HA or placebo group.

One head-to-head study found that 69% of patients given an intermediate-weight HA and 56% of patients given a lower-molecular weight HA achieved the pre-specified MCII for function Three of four placebo-controlled trials that assessed the effect of HA on global improvement reported statistically significant increases in the proportion of HA-treated patients who improved, compared with the proportion of placebo-treated patients who improved.

Too few head-to-head trials were identified to be able to draw any conclusions about the superiority of anyone product over another.

None of the identified studies stratified findings by age, sex, or any other outcome of interest.

The strength of evidence for the conclusion that HA, on average, modestly improves function in patients with knee OA based on placebo-controlled trials is low. The strength of evidence for the conclusion that one HA is better than another, based on head-to-head trials, is insufficient.

#### Intra-articular HA and QoL

Three randomized trials reported on the effects of HA on QoL with mixed results. No conclusions can be drawn about the effects of HA on QoL. As only three trials reported both QoL and functional outcomes, no conclusions can be drawn about the relationship between these two parameters.

The strength of evidence for any conclusions regarding an effect of HA on quality of life is insufficient.

#### Intra-articular HA and Pain

Two large, comprehensive, recent systematic reviews that assessed the literature on the effects of HA on reducing pain compared the effects of HA compared the effects of HA with sham or non- intervention controls or with placebo and all pharmacologic agents on pain reduction, and reported that HA injections significantly reduced pain, both statistically and clinically (that is, the effects reached the MCID/MCII) when measured at 3 months. A 2012 systematic review found that this effect was no longer clinically significant when only double-blind placebo-controlled trials enrolling at least 100 participants per treatment group were included in the analysis. A 2015 network meta-analysis compared the effects of oral and intraarticular pharmacologic agents, oral and intraarticular placebo, and HA on pain at 3 months among 129 RCTs (52 studies compared HA with intraarticular placebo).30 This study reported a significant effect size of HA compared with placebo that exceeded the prespecified absolute MCII; sensitivity analysis showed that limiting study size to 50 or more did not change the effect size but limiting the analysis to studies of 100 or more did reduce the effect size to less than the MCII. In contrast to the 2012 review, the 2015 review found minimal evidence for reporting bias among the placebo-controlled HA studies.

Based on the findings of the two reviews, we believe that the strength of evidence is moderate that HA reduces pain, on average, by an amount about equivalent to the minimum clinically important difference.

#### Intra-articular HA and AEs

The findings of randomized trials, observational studies, and case reports suggest that the adverse events associated with intra-articular injections of HA are nearly all at the site of injection or within the joint, largely confined to pain or swelling, and as likely in the placebo-treated as in the actively treated individual. Serious adverse events are rare. In 24 placebo-controlled trials of HA, serious adverse events were small in number. Estimates are imprecise, and the magnitude of any increase in risk is very small, if present at all. The rate of non-serious AEs was higher but did not differ significantly between the HA-treated and placebo-control groups. The FDA PMA database revealed no post-marketing reports of unexpected adverse events. Information provided by manufacturers about five products was limited to already published data.

The strength of evidence for the conclusion that serious adverse events are rare is moderate. The strength of evidence for a statistically significant difference in SAEs and non-serious AEs between intervention and placebo groups is low.

### Findings in Relation to What is Already Known

To our knowledge, this report represents the first systematic review to attempt to assess the effects of intra-articular HA injections on the combination of delay or avoidance of TKR, pain, function, quality of life, and adverse events.

No other systematic reviews have attempted to synthesize the effects of HA on TKR, and the present review found insufficient evidence to draw a conclusion about the effects of HA on those outcomes.

Regarding the effect of HA on function, we calculated an effect size of −0.23 (95% CI −0.45, −0.01), smaller than the MCID specified in the review by Rutjes but larger than the MCII used in the network meta-analysis by Bannuru (the Rutjes review reported an effect size of −0.33, [95% CI −0.43, −0.22]; the Bannuru review reported an effect size of −0.30 [95% CI −0.40, −0.20] for function).

The smaller effect size we calculated, compared with those of the Rutjes review and the Bannuru review may be attributable to two factors: the smaller number of studies we included and the fact that we sought to pool outcomes for 6 months of followup, whereas the two prior reviews sought to pool outcomes for 3 months of follow-up; thus we may have pooled outcomes when the effect of the HA on function was waning.

Also similar to the Bannuru network meta-analysis, our analysis of the effects of HA on function compared with intraarticular placebo showed no evidence of publication bias.

The moderate effect of HA on function that was identified in the review by Rutjes was no longer considered clinically significant when only large trials (100 or more participants per study arm, or at least 200 per trial) with assessor blinding were considered (−0.09, 95% CI −0.17, 0.00, based on 15 trials).16 The review by Bannuru, which included only double-blind placebo-controlled trials, found no significant difference in effect size when they included only studies enrolling 50 or more participants but did see a decrease in the effect size when they included only studies of 100 or more participants. However study size is not typically a criterion in assessing study quality/risk of bias. Our meta-analysis on the outcome of function included only intraarticular placebo-controlled trials that incorporated assessor blinding; we did not find any studies that met our inclusion criteria that enrolled more than 100 participants per study arm.

The present review is the first to consider only studies of individuals of average age 65 or older. Approximately half of the trials included in the pooled analysis of the effects of HA on pain by Rutjes enrolled populations of average age less than 65; and of the 52 trials they included in their analysis of the effects of HA on function, nearly all included participants of average age less than 65.^16^ No evidence exists that would suggest age would affect the ability to experience pain relief. Therefore, we believe the analyses in the prior reviews by Rutjes and by Bannuru, given the much larger number of included studies, were more adequately powered to assess the effects of HA on pain than would be an analysis limited to the smaller number of studies that enrolled only individuals of average age 65 and over.

The current review found only a small number of serious AEs and in pooling placebo-controlled RCTs, found no statistical differences between serious AEs in treatment and placebo conditions. The 2012 review pooled data on serious AEs from14 trials that reported on AEs and found an increased risk for serious AEs in the HA-treated groups,16 whereas a 2013 review of 29 studies,15 as well as the 2015 network meta-analysis by Bannuru and colleagues found no difference between HA and placebo for any AE, in agreement with the present study. To derive a potential explanation for the disparity in the apparent risk for serious AEs between the review by Rutjes and colleagues and ours, we re-abstracted the data on serious AEs (both those reported by original study authors as being serious, those deemed serious by the criteria of the present study, and those deemed serious by the criteria of the 2012 review). We included only studies that would have met our inclusion criteria (making an exception for mean age); therefore we excluded studies in the Rutjes analysis that were not assessor blinded, studies in which patients served as their own controls, and conference abstracts. The reported increase in risk for serious AEs among patients who received HA compared with placebo in the 2012 review appears to be attributable to several factors. The methods use for the statistical analyses differed slightly between the two reviews. In addition, the criteria used to define serious AEs, the criteria for accepting original authors’ definitions of serious AEs, and the criteria for plausible associations differed between the two reviews; fewer than half of the trials included in the serious AE analysis of the review by Rutjes and colleagues16 actually described specific AEs, and a number of studies that did describe the specific AEs they observed had methodological limitations. The network meta-analysis by Bannuru and colleagues, as well as another recent (2014) meta-analysis by this group compared the efficacy and safety of intraarticular HA with NSAIDs for the treatment of knee OA: Although the small number of studies they were able to pool showed no differences in efficacy between HA and NSAIDs, NSAIDs were associated with a significantly increased risk for gastrointestinal AEs compared with HA We address the issue of adverse event reporting further below in our discussion of limitations.

### Applicability

To increase potential applicability, we limited studies included in the current review with functional outcomes to those with an average age of 65 or older. Nevertheless, no studies excluded patients younger than 65. Given that the only study that assessed factors that might influence the likelihood of undergoing TKR found that age was the only influential factor, age of study participants is likely to be an important consideration for this outcome.

The larger trials included in the assessment of functional outcomes were mostly conducted in academic settings; this typical characteristic of randomized trials tends to limit their applicability to community settings. However a number of the observational studies that addressed the outcome of TKR were conducted in private medical practices.

### Implications for Clinical and Policy Decision Making

The evidence identified for the current study is insufficient to support a decision either way about the efficacy of intra-articular HA injection based on the delay or avoidance of TKR. In addition, the strength of evidence is low regarding the efficacy of HA for improving function in a population 65 years of age or older.

### Limitations of the Comparative Effectiveness Review Process

Given the key questions specified by the partner and specified in our study protocol, we did not attempt to review studies of populations of average age less than 65 years to determine whether they found improvements in function or quality of life. However, removing the exclusion criterion of age for studies that assessed the outcome of TKR, we still identified only three randomized trials that reported TKR, and it was considered a primary outcome in only one study. We also did not contact authors of original research studies to request raw data by patient age and did not attempt to do new pooling of the data on pain in the studies included in the review by Rutjes and colleagues, to include only studies of older populations for reasons explained above.

In addition, as we discuss in the next paragraph (Limitations of the Evidence Base), in choosing the 6-month time point for pooling of effects on function, rather than a shorter follow-up time, we may have underestimated the effect of HA.

### Limitations of the Evidence Base

The majority of trials identified for the current report did not meet the criteria for a low risk of bias, primarily the result of inadequate reporting: Few trials described their recruitment strategy or method for allocation concealment. A number of studies had dropout rates higher than 20% (no studies addressed differences between dropouts and completers), and although most excluded individuals who had recently received corticosteroids or other courses of an HA, most also did not bar participants from using other modes of pain relief, such as NSAIDs. Further, few or no studies attempted to determine whether response to HA differed between groups of patients stratified by characteristics such as baseline age, disease severity (stage) or type; or duration of treatment, few studies followed patients long enough to measure duration of effect, and adverse events were not assessed using any type of standard methodology.

Specific to the outcome of function, no trials measured the duration of effect. A 2011 meta-analysis by Bannuru and colleagues assessed the therapeutic trajectory of intraarticular HA in placebo-controlled trials among patients with knee OA.112 The review identified 54 studies and computed effect sizes for changes from baseline in pain from 4 to 24 weeks. A significant effect size was seen for HA by 4 weeks and this effect peaked at 8 weeks, decreasing thereafter so that only a small effect remained by 6 months. The studies we identified that reported on function at multiple time points were insufficient in number to estimate a trajectory of effect for function.

Specific to the outcome of TKR, only one small RCT measured knee replacement as a primary outcome, and only one trial reported the percentage of participants whose function improved (seven studies reported on the percent who achieved a prespecified level of global improvement, of which four were double-blind placebo-controlled trials).

Another challenging issue for studies of HA is that of the potential placebo effect inherent in the kinds of studies we reviewed. Although we limited our assessment to double-blind placebo-controlled trials (using only intraarticular placebos), the main analysis in the systematic review by Rutjes and colleagues included studies with various types of control groups, including both intraarticular and oral placebo. A 2012 meta-analysis by Colen and colleagues that included 74 studies specifically noted the large effect size for placebo alone (approximately 30%).15 The network meta-analysis by Bannuru and colleagues found that the effect size for intraarticular placebo exceeded that of all active oral treatments for pain,30 prompting a commentary on the role of placebo controls in studies of the treatment of knee OA.113 Identifying the proper control for studies of interventions such as the injection of hyaluronic acid can be challenging, but at the same time, the existing trials, with intraarticular saline controls, are capable of assessing whether HA has any specific active effect over and above that of inexpensive saline.

A related but slightly different issue is that a number of studies allowed the use of rescue medications (acetaminophen, NSAIDs, and less often, CS or opioids) between treatments, which could have eliminated any observable difference between active treatment and placebo. The use of statistical significance vs. clinical significance in studies such as the ones included in this review (as well as the review itself) also needs to be mentioned. The attainment of both statistical significance and MCID or MCII is critical for demonstrating effectiveness of any clinical treatment. However the threshold chosen for the MCID/MCII and how it is applied is controversial.114 The evidence is limited as to what the MCID/MCII should be for an effect of HA on function, whether it should be the same as for pain, and whether it should be limited to the use of only certain outcome measures. In trying to interpret our results regarding HA and function, we used three levels of MICD that have been proposed and used by others: our observed effect size exceeded the lower MCIIs of 0.12 and 0.2 but did not meet the one used in the review by Rutjes, 0.37 (an effect size of 0.2–0.4 is normally considered small to moderate according to Cohen's classification). But we acknowledge as a limitation that additional research could improve estimates of the MCID/MCII. Perhaps more importantly, we identified almost no studies that reported the proportion of patients who achieved either a statistical or clinical improvement.

Finally an issue of possible concern is that many studies of HA show potential financial conflict of interest (FCOI), either direct industry funding of the research or employment of authors by manufacturers of the agents being tested.78,81 A 2013 systematic review examined 48 trials of intraarticular HA for the treatment of knee OA to determine whether industry sponsorship was associated with the likelihood of a positive finding. Of 33 trials that identified a sponsor, 30 were industry sponsored; therefore, determining whether industry sponsorship affected outcomes was impossible. However the study also assessed the association between industry authorship (compared with academic authorship) and outcomes. Of the 17 studies with industry authors, none reported unfavorable conclusions (all reported favorable or neutral conclusions); 11 of the 31 academic authored studies reported unfavorable conclusions and 9 reported neutral conclusions. Another 2013 systematic review assessed only studies of HA that employed US-approved HA products; this review, which identified 29 studies and was funded by a trade group representing the pharm industry, reported statistically and clinically significant pooled effects sizes for the outcomes of pain and function compared with saline controls and no difference in serious AEs.78 However, the 2015 network meta-analysis by Bannuru and colleagues reported comparable effect sizes and was funded by the Agency for Healthcare Research and Quality.

### Research Gaps

Many of the research gaps we identified were discussed in the previous section on the limitations of the evidence base. This section presents several specific research needs based on the outcomes of greatest interest.

Clear research gaps exist regarding studies of the effectiveness of HA among individuals 65 years of age and older and the effect of HA, if any, on delay or avoidance of TKR. Two searches for ongoing studies of HA and OA of the knee on Clinicaltrials.gov and review of entries provided by manufacturers revealed no completed, ongoing, or recruiting studies on older individuals with knee OA or with outcomes of TKR. The observational studies identified for this review could not definitively answer the question of whether HA delays or prevents the need for TKR. However, data from any of the large administrative databases maintained by commercial payers offer an alternate possibility. TKR Preliminary findings of three such studies have been presented at two recent meetings. An abstract presented at the 2013 meeting of the American College of Rheumatology reported using the Truven Marketscan database to match 7,000 HA recipients (66% female) with 19,627 non-recipients with OA of the knee (propensity score matching with the non-HA cohort was 98%).115 With one episode of HA treatment, the median times from the initial specialist visit to TKR were 199 and 443 days for the non-HA cohort and HA cohort, respectively. Additional treatment episodes increased the median gap by an average 202 days, suggesting true dose-response.

The findings of two similar audits of health plan claims were presented at the 2014 annual meeting of the Academy of Managed Care Pharmacy.116 An industry-sponsored study identified 18,217 patients who initiated treatment between 2007 and 2010 and were followed for 3 years, some receiving 5 or more courses of treatment. Successive courses of HA led to greater proportions of patients without TKR at 3 years: 96.3% of those who received 5 or more courses avoided TKR compared with 72.7% who received 1 course (HR 0.113, p<0.0001). In a study funded by a major insurance provider, among 2,728 patients with confirmed diagnoses of OA of the knee who received a first dose of HA, 35% underwent knee surgery within the first year and another 34.2% underwent surgery the second year. However the study did not specify the type of surgery and included patients who had undergone prior knee surgery; thus the authors concluded that although 69% of patients underwent surgery (of some type) within two years of treatment, further research is needed that enrolls patients with appropriate eligibility criteria.117

The decision to undergo TKR is difficult to predict, as it is affected by a number of factors besides severity of osteoarthritis, such as age, comorbidities, pain tolerance, activity level, aversion to surgical intervention, and expectations about one’s life expectancy; OMERACT has considered this issue and has suggested considering two alternative outcomes for assessing the effect of treatments for knee OA: “time to physician’s decision to recommend surgery” and “time to fulfilling criterial for total joint replacement.”118 However, if the primary question of interest is whether or not intraarticular HA can delay joint replacement, a double-blind placebo controlled trial could be conducted that enrolls a group of people who have already been deemed “appropriate for surgery” and randomizes them to receive intraarticular HA or an intra-articular placebo. Comparison of the time to TKR could then be appropriately compared. We did identify one small pilot study that employed this design, the study conducted by Blanco and colleagues, which reported a delay in time to TKR in the HA group that did not achieve statistical significance.47

Research is also needed to confirm the suggestion that higher molecular weight, more cross-linked HA products are more effective than lower molecular weight products: a subgroup analysis in the review by Rutjes suggested a trend toward greater pain relief for very high molecular weight products but studies are needed to assess whether this observation generalizes to function and also to compare the newer, larger products with the smaller ones.

Another issue of concern is the effectiveness (and safety) of HA over time and with repeated treatment cycles. Given that most studies of HA have been 6 months or less in duration and that OA of the knee is a chronic condition, studies are needed to assess both the safety and effectiveness of repeated cycles of HA over time and whether HA decreases the need for pharmacotherapy (NSAIDS, corticosteroids, and opioids), which has its own safety concerns.

Finally, as discussed above, the way that AEs are recorded and reported merits concern. Although issues such as potential underreporting affect active interventions as well as placebo-treated controls within the same study, the disparity in that of Bannuru reinforces the need for standardization in the way that adverse events are documented. Based on a systematic review conducted in 2013, a group of researchers has developed an ACTTION (Analgesic, Anesthetic, and Addiction Clinical Trial Translations, Innovations, Opportunities, and Networks) AE checklist to improve the accuracy and completeness of AE data abstracted from reports of trials.119

We advocate analyzing data from any of the large administrative databases maintained by commercial payers, to answer the question as to whether beneficiaries who are treated with intra-articular HA proceed to TKR at a slower rate than do those who do not receive HA. We realize that a number of factors might affect the decision to undergo TKR, such as age, comorbidities, pain tolerance, activity level, aversion to surgical intervention, and expectations about one’s life expectancy; at least some of these factors could be controlled for in a large, well-designed case control study, although an RCT would be needed to provide a definitive answer.

### Conclusions

Trials enrolling older participants show a small, statistically significant effect of HA on function. Whether this effect is clinically meaningful is less clear: The research literature varies on its definition of minimum clinically important improvement. Based on our analyses, HA demonstrated clinically important improvements using two out of three of these definitions for this assessment. HA shows relatively few serious adverse events; however no studies limited participation to those 65 years or older. No conclusions can be drawn from the available literature on delay or avoidance of TKR through the use of HA. Studies that can compare large numbers of treated and untreated individuals, preferably with a randomized design, are needed to answer this question.

#### References

1 Lawrence RC, Felson DT, Helmick CG, et al. Estimates of the prevalence of arthritis and other rheumatic conditions in the United States. Part II. Arthritis Rheum. Jan. 2008;58(1):26-35. [pmid: 18163497].
2 Dillon CF, Rasch EK, Gu Q, et al. Prevalence of knee osteoarthritis in the United States: arthritis data from the Third National Health and Nutrition Examination Survey 1991-94. J Rheumatol. Nov. 2006;33(11):2271-2279. [pmid: 17013996].
3 Richmond SA, Fukuchi RK, Ezzat A, et al. Are Joint Injury, Sport Activity, Physical Activity, Obesity, or Occupational Activities Predictors for Osteoarthritis? A Systematic Review. J Orthop Sports Phys Ther. 2013. Jun. 11. [pmid: 23756344].
4 Murphy L, Schwartz TA, Helmick CG, et al. Lifetime risk of symptomatic knee osteoarthritis. Arthritis Rheum. Sep. 15. 2008;59(9):1207-1213. [pmid: 18759314].
5 Weinstein AM, Rome BN, Reichmann WM, et al. Estimating the burden of total knee replacement in the United States. J Bone Joint Surg Am. Mar. 6. 2013;95(5):385-392. [pmid: 23344005].
6 Teichtahl AJ, Wluka AE, Wang Y, et al. The longitudinal relationship between changes in body weight and changes in medial tibial cartilage, and pain among community-based adults with and without meniscal tears. Ann Rheum Dis. 2013. Jun. 6. [pmid: 23744978].
7 Schiphof D, de Klerk BM, Kerkhof HJ, et al. Impact of different descriptions of the Kellgren and Lawrence classification criteria on the diagnosis of knee osteoarthritis. Ann Rheum Dis. Aug. 2011;70(8):1422-1427. [pmid: 21555325].
8 Cibere J, Zhang H, Thorne A, et al. Association of clinical findings with pre-radiographic and radiographic knee osteoarthritis in a population-based study. Arthritis Care Res (Hoboken). Dec. 2010;62(12):1691-1698. [pmid: 20665737].
9 Hochberg MC, Altman RD, April KT, et al. American College of Rheumatology 2012 recommendations for the use of nonpharmacologic and pharmacologic therapies in osteoarthritis of the hand, hip, and knee. Arthritis Care Res (Hoboken). Apr. 2012;64(4):465-474. [pmid: 22563589].
10 Fraser JR, Laurent TC, Laurent UB. Hyaluronan: its nature, distribution, functions and turnover. J Intern Med. Jul. 1997;242(1):27-33. [pmid: 9260563].
11 Watterson JR, Esdaile JM. Viscosupplementation: therapeutic mechanisms and clinical potential in osteoarthritis of the knee. J Am Acad Orthop Surg. Sep-Oct. 2000;8(5):277-284. [pmid: 11029555].
12 Bannuru RR, Natov NS, Obadan IE, et al. Therapeutic trajectory of hyaluronic acid versus corticosteroids in the treatment of knee osteoarthritis: a systematic review and meta-analysis. Arthritis Rheum. Dec. 15. 2009;61(12):1704-1711. [pmid: 19950318].
13 Brzusek D, Petron D. Treating knee osteoarthritis with intra-articular hyaluronans. Curr Med Res Opin. Dec. 2008;24(12):3307-3322. [pmid: 18954498].
14 Brander VA, Stadler TS. Functional improvement with hylan G-F 20 in patients with knee osteoarthritis. Phys Sportsmed. Oct. 2009;37(3):38-48. [pmid: 20048527].
15 Colen S, van den Bekerom MP, Mulier M, et al. Hyaluronic acid in the treatment of knee osteoarthritis: a systematic review and meta-analysis with emphasis on the efficacy of different products. BioDrugs. Aug. 1. 2012;26(4):257-268. [pmid: 22734561].
16 Rutjes AW, Juni P, da Costa BR, et al. Viscosupplementation for osteoarthritis of the knee: a systematic review and meta-analysis. Ann Intern Med. Aug. 7. 2012;157(3):180-191. [pmid: 22868835].
17 Lo GH, LaValley M, McAlindon T, et al. Intra-articular hyaluronic acid in treatment of knee osteoarthritis: a meta-analysis. JAMA. Dec. 17. 2003;290(23):3115-3121. [pmid: 14679274].
18 Zhang W, Nuki G, Moskowitz RW, et al. OARSI recommendations for the management of hip and knee osteoarthritis: part III: Changes in evidence following systematic cumulative update of research published through January 2009. Osteoarthritis Cartilage. Apr. 2010;18(4):476-499. [pmid: 20170770].
19 American Academy of Orthopaedic Surgeons. Treatment of Osteoarthritis of the Knee. 2nd Edition: SUMMARY OF RECOMMENDATIONS. http://www.aaos.org/research/guidelines/OAKSummaryofRecommendations.pdf.
20 Bellamy N, Buchanan WW, Goldsmith CH, et al. Validation study of WOMAC: a health status instrument for measuring clinically important patient relevant outcomes to antirheumatic drug therapy in patients with osteoarthritis of the hip or knee. J Rheumatol. Dec. 1988;15(12):1833-1840. [pmid: 3068365].
21 Lequesne MG, Mery C, Samson M, et al. Indexes of severity for osteoarthritis of the hip and knee. Validation--value in comparison with other assessment tests. Scand J Rheumatol Suppl. 1987;65:85-89. [pmid: 3479839].
22 Roos EM, Roos HP, Lohmander LS, et al. Knee Injury and Osteoarthritis Outcome Score (KOOS)--development of a self-administered outcome measure. J Orthop Sports Phys Ther. Aug. 1998;28(2):88-96. [pmid: 9699158].
23 Terwee CB, Coopmans C, Peter WF, et al. Development and Validation of the Computer-Administered Animated Activity Questionnaire to Measure Physical Functioning of Patients With Hip or Knee Osteoarthritis. Phys Ther. 2013. Sep. 12. [pmid: 24029297].
24 Pham T, van der Heijde D, Altman RD, et al. OMERACT-OARSI initiative: Osteoarthritis Research Society International set of responder criteria for osteoarthritis clinical trials revisited. Osteoarthritis Cartilage. May. 2004;12(5):389-399. [pmid: 15094138].
25 RAND Corporation. 36-Item Short Form Survey from the RAND Medical Outcomes Study. RAND Corporation. Accessed on November 6 2013. http://www.rand.org/health/surveys_tools/mos/mos_core_36item.html.
26 Lingard EA, Katz JN, Wright EA, et al. Predicting the outcome of total knee arthroplasty. J Bone Joint Surg Am. Oct. 2004;86-A(10):2179-2186. [pmid: 15466726].
27 Medicare Policies and Guidelines: Viscosupplementation Therapy (L26616). http://www.findacode.com/medicare/policies-guidelines/display-medicare-info.php?type=LCD&type_id=26616&title=viscosupplementation-therapy-l26616.
28 Cornell JE, Mulrow CD, Localio R, et al. Random-Effects Meta-analysis of Inconsistent Effects: A Time for Change. Ann Intern Med. Feb. 18. 2014;160(4). [pmid: 24727843].
29 IntHout J, Ioannidis JP, Borm GF. The Hartung-Knapp-Sidik-Jonkman method for random effects meta-analysis is straightforward and considerably outperforms the standard DerSimonian-Laird method. BMC Med Res Methodol. 2014;14:25. [pmid: 24548571].
30 Bannuru RR, Schmid CH, Kent DM, et al. Comparative Effectiveness of Pharmacologic Interventions for Knee Osteoarthritis: A Systematic Review and Network Meta-analysis. Annals of Internal Medicine. 2015;162(1):46-54. [pmid: 25560713].
31 Angst F, Aeschlimann A, Stucki G. Smallest detectable and minimal clinically important differences of rehabilitation intervention with their implications for required sample sizes using WOMAC and SF-36 quality of life measurement instruments in patients with osteoarthritis of the lower extremities. Arthritis Rheum. Aug. 2001;45(4):384-391. [pmid: 11501727].
32 Wandel S, Juni P, Tendal B, et al. Effects of glucosamine, chondroitin, or placebo in patients with osteoarthritis of hip or knee: network meta-analysis. BMJ. 2010;341:c4675. [pmid: 20847017].
33 Tubach F, Ravaud P, Martin-Mola E, et al. Minimum clinically important improvement and patient acceptable symptom state in pain and function in rheumatoid arthritis, ankylosing spondylitis, chronic back pain, hand osteoarthritis, and hip and knee osteoarthritis: Results from a prospective multinational study. Arthritis Care Res (Hoboken). Nov. 2012;64(11):1699-1707. [pmid: 22674853].
34 Pham T, Van Der Heijde D, Lassere M, et al. Outcome variables for osteoarthritis clinical trials: The OMERACT-OARSI set of responder criteria. J Rheumatol. Jul. 2003;30(7):1648-1654. [pmid: 12858473].
35 Begg CB, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. Dec. 1994;50(4):1088-1101. [pmid: 7786990].
36 Egger M, Smith GD, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. British Medical Journal. Sep. 13. 1997;315(7109):629-634. PMID: WOS:A1997XW69400016. [pmid: 9310563].
37 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-560. [pmid: 12958120].
38 Higgins JP, Altman DG, Gotzsche PC, et al. The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. BMJ. 2011;343:d5928. [pmid: 22008217].
39 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. 2008. [pmid: 22479713].
40 Wells GA, Shea B, O'Connell D, et al. The Newcastle-Ottawa Quality Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. 2010.
41 Santaguida PL PR. The Development of the McHarm Quality Assessment Scale for adverse events: Delphi Consensus on important criteria for evaluating harms. 2008. Available at: http://hiru.mcmaster.ca/epc/mcharm.pdf.
42 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
43 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-523. [pmid: 19595577].
44 Berkman ND, Lohr KN, Ansari M, et al. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville (MD). 2008.
45 Dougados M, Nguyen M, Listrat V, et al. High molecular weight sodium hyaluronate (hyalectin) in osteoarthritis of the knee: a 1 year placebo-controlled trial. Osteoarthritis Cartilage. Apr. 1993;1(2):97-103. [pmid: 8886085].
46 Forster MC, Straw R. A prospective randomised trial comparing intra-articular Hyalgan injection and arthroscopic washout for knee osteoarthritis. Knee. Sep. 2003;10(3):291-293. [pmid: 12893153].
47 Blanco FJ, Fernandez-Sueiro JL, Pinto-Tasende JA, et al. Intra-Articular Hyaluronan Treatment of Patients with Knee Osteoarthritis Waiting for Replacement Surgery. The Open Arthritis Journal. 2008;1:1-7.
48 Barrett JP, Siviero P. Retrospective study of outcomes in hyalgan(R)-treated patients with osteoarthritis of the knee. Clin Drug Investig. 2002;22(2):87-97. [pmid: 23315396].
49 Campbell DG, Angel KR, Dobson PJ, et al. Experiences of viscosupplementation for knee osteoarthritis. Aust Fam Physician. Oct. 2004;33(10):863-864. [pmid: 15532168].
50 Evanich JD, Evanich CJ, Wright MB, et al. Efficacy of intraarticular hyaluronic acid injections in knee osteoarthritis. Clin Orthop Relat Res. Sep. 2001;(390):173-181. [pmid: 11550864].
51 Mazieres B, Bard H, Ligier M, et al. Medicoeconomic evaluation of hyaluronic acid for knee osteoarthritis in everyday practice: the MESSAGE study. Joint Bone Spine. Oct. 2007;74(5):453-460. [pmid: 17921022].
52 Waddell DD, Joseph B. Delayed Total Knee Replacement with Hylan G-F 20. J Knee Surg. 2014. Oct. 28. [pmid: 25349988].
53 Neustadt DH. Long-term efficacy and safety of intra-articular sodium hyaluronate (Hyalgan) in patients with osteoarthritis of the knee. Clin Exp Rheumatol. May-Jun. 2003;21(3):307-311. [pmid: 12846048].
54 Romero Jurado M, Enrique Fidalgo A, Rodriguez Villar V, et al. Factors related with the time to surgery in waiting-list patients for knee prostheses. Reumatol Clin. May-Jun. 2013;9(3):148-155. [pmid: 23453189].
55 Turajane T, Amphansap T, Labpiboonpong V, et al. Total knee replacement following repeated cycles of intra-articular sodium hyaluronate (500-730 Kda) in failed conservative treatment of knee osteoarthritis: a 54-month follow-up. J Med Assoc Thai. Dec. 2009;92(Suppl 6):S63-S68. [pmid: 20120667].
56 Turajane T, Labpiboonpong V, Maungsiri S. Cost analysis of intra-articular sodium hyaluronate treatment in knee osteoarthritis patients who failed conservative treatment. J Med Assoc Thai. Sep. 2007;90(9):1839-1844. [pmid: 17957928].
57 Turajane T, Tanavaree A, Labpiboonpong V, et al. Outcomes of intra-articular injection of sodium hyaluronate for the treatment of osteoarthritis of the knee. J Med Assoc Thai. Sep. 2007;90(9):1845-1852. [pmid: 17957929].
58 Waddell DD, Bricker DC. Clinical experience with the effectiveness and tolerability of hylan G-F 20 in 1047 patients with osteoarthritis of the knee. J Knee Surg. Jan. 2006;19(1):19-27. [pmid: 16468490].
59 Waddell DD, Cefalu CA, Bricker DC. A second course of hylan G-F 20 for the treatment of osteoarthritic knee pain: 12-month patient follow-up. J Knee Surg. Jan. 2005;18(1):7-15. [pmid: 15742592].
60 Anand A, Balduini F, Rogers K. Hyaluronic acid in management of advanced osteoarthritis of the knee: Retrospective analysis. European Journal of Orthopaedic Surgery and Traumatology. December. 2010;20(8):645-649. FULL TEXT LINK http://dx.doi.org/10.1007/s00590-010-0635-3.
61 Korkmaz M, Erdogan Y, Okur A, et al. Comparison of the effects of intraarticular hyaluronic acid and antiinflammatory drug treatments on the surgical intervention rates in patients with gonarthrosis. Turkish Journal of Medical Sciences. 2013;43(2):222-226. 2013; FULL TEXT LINK http://dx.doi.org/10.3906/sag-1205-122.
62 Whitman CS, Allen D, Comadoll JL, et al. A retrospective study of SUPARTZ and repeat treatment for osteoarthritis pain in the knee. Journal of Managed Care Medicine. 2010;13:43-47.
63 Waddell DD, Bricker DC. Total knee replacement delayed with Hylan G-F 20 use in patients with grade IV osteoarthritis. J Manag Care Pharm. Mar. 2007;13(2):113-121. [pmid: 17330972].
64 Berenbaum F, Grifka J, Cazzaniga S, et al. A randomised, double-blind, controlled trial comparing two intra-articular hyaluronic acid preparations differing by their molecular weight in symptomatic knee osteoarthritis. Ann Rheum Dis. Sep. 2012;71(9):1454-1460. [pmid: 22294639].
65 Dixon AS, Jacoby RK, Berry H, et al. Clinical trial of intra-articular injection of sodium hyaluronate in patients with osteoarthritis of the knee. Curr Med Res Opin. 1988;11(4):205-213. [pmid: 3063436].
66 Karlsson J, Sjogren LS, Lohmander LS. Comparison of two hyaluronan drugs and placebo in patients with knee osteoarthritis. A controlled, randomized, double-blind, parallel-design multicentre study. Rheumatology (Oxford). Nov. 2002;41(11):1240-1248. [pmid: 12421996].
67 Khanasuk Y, Dechmaneenin T, Tanavalee A. Prospective randomized trial comparing the efficacy of single 6-ml injection of hylan G-F 20 and hyaluronic acid for primary knee arthritis: a preliminary study. J Med Assoc Thai. Oct. 2012;95(Suppl 10):S92-S97. [pmid: 23451445].
68 Pavelka K, Uebelhart D. Efficacy evaluation of highly purified intra-articular hyaluronic acid (Sinovial((R))) vs hylan G-F20 (Synvisc((R))) in the treatment of symptomatic knee osteoarthritis. A double-blind, controlled, randomized, parallel-group non-inferiority study. Osteoarthritis Cartilage. Nov. 2011;19(11):1294-1300. [pmid: 21875678].
69 Raman R, Dutta A, Day N, et al. Efficacy of Hylan G-F 20 and Sodium Hyaluronate in the treatment of osteoarthritis of the knee -- a prospective randomized clinical trial. Knee. Aug. 2008;15(4):318-324. [pmid: 18430574].
70 Brandt KD, Block JA, Michalski JP, et al. Efficacy and safety of intraarticular sodium hyaluronate in knee osteoarthritis. ORTHOVISC Study Group. Clin Orthop Relat Res. Apr. 2001;R385:130-143. [pmid: 11302304].
71 DeCaria JE, Montero-Odasso M, Wolfe D, et al. The effect of intra-articular hyaluronic acid treatment on gait velocity in older knee osteoarthritis patients: a randomized, controlled study. Arch Gerontol Geriatr. Sep-Oct. 2012;55(2):310-315. [pmid: 22169699].
72 Huang TL, Chang CC, Lee CH, et al. Intra-articular injections of sodium hyaluronate (Hyalgan(R)) in osteoarthritis of the knee. a randomized, controlled, double-blind, multicenter trial in the Asian population. BMC Musculoskelet Disord. 2011;12:221. [pmid: 21978211].
73 Huskisson EC, Donnelly S. Hyaluronic acid in the treatment of osteoarthritis of the knee. Rheumatology (Oxford). Jul. 1999;38(7):602-607. [pmid: 10461471].
74 Lundsgaard C, Dufour N, Fallentin E, et al. Intra-articular sodium hyaluronate 2 mL versus physiological saline 20 mL versus physiological saline 2 mL for painful knee osteoarthritis: a randomized clinical trial. Scandinavian Journal of Rheumatology. Mar-Apr. 2008;37(2):142-150. PMID: WOS:000255956000011. [pmid: 18415773].
75 Petrella RJ, DiSilvestro MD, Hildebrand C. Effects of hyaluronate sodium on pain and physical functioning in osteoarthritis of the knee: a randomized, double-blind, placebo-controlled clinical trial. Arch Intern Med. Feb. 11. 2002;162(3):292-298. [pmid: 11822921].
76 Pham T, Le Henanff A, Ravaud P, et al. Evaluation of the symptomatic and structural efficacy of a new hyaluronic acid compound, NRD101, in comparison with diacerein and placebo in a 1 year randomised controlled study in symptomatic knee osteoarthritis. Ann Rheum Dis. Dec. 2004;63(12):1611-1617. [pmid: 15331394].
77 Kahan A, Lleu PL, Salin L. Prospective randomized study comparing the medicoeconomic benefits of Hylan GF-20 vs. conventional treatment in knee osteoarthritis. Joint Bone Spine. Aug. 2003;70(4):276-281. [pmid: 12951310].
78 Miller LE, Block JE. US-Approved Intra-Articular Hyaluronic Acid Injections are Safe and Effective in Patients with Knee Osteoarthritis: Systematic Review and Meta-Analysis of Randomized, Saline-Controlled Trials. Clin Med Insights Arthritis Musculoskelet Disord. 2013;6:57-63. [pmid: 24027421].
79 Trigkilidas D, Anand A. The effectiveness of hyaluronic acid intra-articular injections in managing osteoarthritic knee pain. Ann R Coll Surg Engl. Nov. 2013;95(8):545-551. [pmid: 24165334].
80 Bannuru RR, Vaysbrot EE, Sullivan MC, et al. Relative efficacy of hyaluronic acid in comparison with NSAIDs for knee osteoarthritis: A systematic review and meta-analysis. Seminars in Arthritis and Rheumatism. 2013.
81 Printz JO, Lee JJ, Knesek M, et al. Conflict of interest in the assessment of hyaluronic acid injections for osteoarthritis of the knee: an updated systematic review. J Arthroplasty. Sep. 2013;28(8 Suppl):30-33 e1. [pmid: 23890521].
82 Grecomoro G, Martorana U, Di Marco C. Intra-articular treatment with sodium hyaluronate in gonarthrosis: a controlled clinical trial versus placebo. Pharmatherapeutica. 1987;5(2):137-141. [pmid: 3310017].
83 Altman RD, Moskowitz R. Intraarticular sodium hyaluronate (Hyalgan) in the treatment of patients with osteoarthritis of the knee: a randomized clinical trial. Hyalgan Study Group. J Rheumatol. Nov. 1998;25(11):2203-2212. [pmid: 9818665].
84 Henderson EB, Smith EC, Pegley F, et al. Intra-articular injections of 750 kD hyaluronan in the treatment of osteoarthritis: a randomised single centre double-blind placebo-controlled trial of 91 patients demonstrating lack of efficacy. Ann Rheum Dis. Aug. 1994;53(8):529-534. [pmid: 7944639].
85 Leopold SS, Redd BB, Warme WJ, et al. Corticosteroid compared with hyaluronic acid injections for the treatment of osteoarthritis of the knee. A prospective, randomized trial. J Bone Joint Surg Am. Jul. 2003;85-A(7):1197-1203. [pmid: 12851342].
86 Petrella RJ, Cogliano A, Decaria J. Combining two hyaluronic acids in osteoarthritis of the knee: a randomized, double-blind, placebo-controlled trial. Clin Rheumatol. Aug. 2008;27(8):975-981. [pmid: 18204873].
87 Roman JA, Chismol J, Morales M, et al. Intra-articular treatment with hyaluronic acid. Comparative study of Hyalgan and Adant. Clin Rheumatol. 2000;19(3):204-206. [pmid: 10870655].
88 Tamir E, Robinson D, Koren R, et al. Intra-articular hyaluronan injections for the treatment of osteoarthritis of the knee: a randomized, double blind, placebo controlled study. Clin Exp Rheumatol. May-Jun. 2001;19(3):265-270. [pmid: 11407078].
89 Petrella RJ, Decaria J, Petrella MJ. Long term efficacy and safety of a combined low and high molecular weight hyaluronic acid in the treatment of osteoarthritis of the knee. Rheumatology Reports. 2011;3(1):16-21. 2011; FULL TEXT LINK http://dx.doi.org/10.4081/rr.2011.e4.
90 Kemper F, Gebhardt U, Meng T, et al. Tolerability and short-term effectiveness of hylan G-F 20 in 4253 patients with osteoarthritis of the knee in clinical practice. Curr Med Res Opin. Aug. 2005;21(8):1261-1269. [pmid: 16083536].
91 Petrella RJ. Hyaluronic acid for the treatment of knee osteoarthritis: long-term outcomes from a naturalistic primary care experience. Am J Phys Med Rehabil. Apr. 2005;84(4):278-283. quiz 84, 93. [pmid: 15785261].
92 Waddell DD, Bricker DC. Hylan G-F 20 tolerability with repeat treatment in a large orthopedic practice: a retrospective review. J Surg Orthop Adv. Spring. 2006;15(1):53-59. [pmid: 16603113].
93 Petrella RJ, Cogliano A, Decaria J. Comparison of avian and nonavian hyaluronic acid in osteoarthritis of the knee. Orthopedic Research and Reviews. 2010;2:5-9.
94 Bernardeau C, Bucki B, Liote F. Acute arthritis after intra-articular hyaluronate injection: onset of effusions without crystal. Ann Rheum Dis. May. 2001;60(5):518-520. [pmid: 11302877].
95 Idrissi Z, Benbouazza K, Fourtassi M, et al. Acute pseudo-septic arthritis following viscosuplementation of the knee. Pan Afr Med J. 2012;12:44. [pmid: 22937184].
96 Iizuka M, Yao R, Wainapel S. Saphenous nerve injury following medial knee joint injection: a case report. Arch Phys Med Rehabil. Oct. 2005;86(10):2062-2065. [pmid: 16213255].
97 Kunugiza Y, Tani M, Tomita T, et al. Staphylococcal scalded skin syndrome after intra-articular injection of hyaluronic acid. Mod Rheumatol. Jun. 2011;21(3):316-319. [pmid: 21188450].
98 Lequerre T, Nouvellon M, Kraznowska K, et al. Septic arthritis due to Actinomyces naeslundii: report of a case. Joint Bone Spine. Oct. 2002;69(5):499-501. [pmid: 12477236].
99 Maillefert JF, Hirschhorn P, Pascaud F, et al. Acute attack of chondrocalcinosis after an intraarticular injection of hyaluronan. Rev Rhum Engl Ed. Oct. 1997;64(10):593-594. [pmid: 9385702].
100 Martens PB. Bilateral symmetric inflammatory reaction to hylan G-F 20 injection. Arthritis Rheum. Apr. 2001;44(4):978-979. [pmid: 11315938].
101 Michou L, Job-Deslandre C, de Pinieux G, et al. Granulomatous synovitis after intraarticular Hylan GF-20. A report of two cases. Joint Bone Spine. Sep. 2004;71(5):438-440. [pmid: 15474399].
102 Pullman-Mooar S, Mooar P, Sieck M, et al. Are there distinctive inflammatory flares after hylan g-f 20 intraarticular injections?. J Rheumatol. Dec. 2002;29(12):2611-2614. [pmid: 12465161].
103 Rees JD, Wojtulewski JA. Systemic reaction to viscosupplementation for knee osteoarthritis. Rheumatology (Oxford). Dec. 2001;40(12):1425-1426. [pmid: 11752524].
104 Roos J, Epaulard O, Juvin R, et al. Acute pseudoseptic arthritis after intraarticular sodium hyaluronan. Joint Bone Spine. Jul. 2004;71(4):352-354. [pmid: 15288866].
105 Shemesh S, Heller S, Salai M, et al. Septic arthritis of the knee following intraarticular injections in elderly patients: report of six patients. Isr Med Assoc J. Dec. 2011;13(12):757-760. [pmid: 22332447].
106 Tahiri L, Benbouazza K, Amine B, et al. Acute pseudoseptic arthritis after viscosupplementation of the knee: a case report. Clin Rheumatol. Nov. 2007;26(11):1977-1979. [pmid: 17436053].
107 Wendling D, Royer F, Chabroux A, et al. Acute gouty arthritis after intraarticular hyaluronate injection. Joint Bone Spine. Dec. 2007;74(6):664-665. [pmid: 17900963].
108 Ali Y, Weinstein M, Jokl P. Acute pseudogout following intra-articular injection of high molecular weight hyaluronic acid [2]. American Journal of Medicine. 1999;107(6):641-642. 1999; MEDLINE PMID 10625037 (http://www.ncbi.nlm.nih.gov/pubmed/10625037) FULL TEXT LINK http://dx.doi.org/10.1016/S0002-9343(99)00255-7. [pmid: 10625037].
109 Banerjee M. Eosinophiluria from intra-articular hyaluronic acid injection. Clinical and Experimental Nephrology. Dec. 2002;6(4):248-249. FULL TEXT LINK http://dx.doi.org/10.1007/s101570200042.
110 Semih T, Bilgen O, Cemile E, et al. Herpes zoster development after intraarticular sodium hyaluronate injection. Journal of Musculoskeletal Pain. February. 2009;17(1):86-89. FULL TEXT LINK http://dx.doi.org/10.1080/10582450802679797.
111 Calvo M, Tornero P, De Barrio M, et al. Erytema multiform due to hyaluronic acid (Go-On). Journal of Investigational Allergology and Clinical Immunology. 2007;17(2):127-128. PMID: WOS:000246236700012. [pmid: 17460954].
112 Bannuru RR, Natov NS, Dasi UR, et al. Therapeutic trajectory following intra-articular hyaluronic acid injection in knee osteoarthritis--meta-analysis. Osteoarthritis Cartilage. Jun. 2011;19(6):611-619. [pmid: 21443958].
113 Mandl LA, Losina E. Relative efficacy of knee osteoarthritis treatments: are all placebos created equal?. Ann Intern Med. Jan. 6. 2015;162(1):71-72. [pmid: 25560716].
114 Bannuru RR, Vaysbrot EE, McIntyre LF. Did the American Academy of Orthopaedic Surgeons osteoarthritis guidelines miss the mark?. Arthroscopy. Jan. 2014;30(1):86-89. [pmid: 24384274].
115 Do Hyaluronic Acid Injections Delay Total Knee Replacement Surgery?. Abstract:#2139. 2013. October. 29.
116 Dasa V, DeKowen M, Lim S, Long K, Heeckt P. M12. Effectiveness of Repeated Courses of Hyaluronic Acid Injections on the Time to Total Knee Replacement Surgery: Evidence from a Large U.S. Health Plan Claims Database. Academy of Managed Care Pharmacy 2014 Nexus; 2014 October 7-10; Boston, Massachusetts. Journal of Managed Care and Specialty Pharmacy. 20:10-A. s53.
117 Khan T, Nanchanatt G, Jan SA, Farber K. M10. Analysis of the Effectiveness of Hyaluronic Acid in Prevention of Knee Surgery in Osteoarthritis Patients 26th Annual Meeting and Exp; 2014; Tampa, Florida. Journal of Managed Care and Specialty Pharmacy. 20:4-A. S49.
118 Maillefert JF, Hawker GA, Gossec L, et al. Concomitant therapy: an outcome variable for musculoskeletal disorders? Part 2: total joint replacement in osteoarthritis trials. J Rheumatol. Dec. 2005;32(12):2449-2451. [pmid: 16331784].
119 Smith SM, Wang AT, Katz NP, et al. Adverse event assessment, analysis, and reporting in recent published analgesic clinical trials: ACTTION systematic review and recommendations. Pain. Jul. 2013;154(7):997-1008. [pmid: 23602344].