# Peer Reviewers

- James Katz, MD
  National Institute of Arthritis and Musculoskeletal and Skin Diseases (NIAMS)
  Director, Rheumatology Fellowship and Training Branch

- Courtland G. Lewis, MD
  Physician in Chief
  Hartford Healthcare Bone and Joint Institute Hartford, CT

- Grace Lo, MD, MSc
  Baylor College of Medicine
  Michael E. DeBakey VA Medical Center