# Abbreviations / Acronyms

ADL: Activities of Daily Living
AEs: Adverse Events
AHRQ: Agency for Healthcare Research and Quality
CMS: Centers for Medicare and Medicaid Services
DJD: Degenerative Joint Disease
FDA: Food and Drug Administration
HA: Hyaluronic acid
HRQoL: Health-Related Quality of life
IADLs: Instrumental Activities of Daily Living
KOOS: Knee Injury and Osteoarthritis Outcomes Score
TKR: Knee Replacement
MCID: Minimum clinically important difference
MCII: Minimum Clinically Important Improvement
OA: Osteoarthritis
OARSI: Osteoarthritis Research Society International
OMERACT: Outcome Measures in Rheumatology
OR: Odds-Ratio
PICOTs: Participants, Interventions, Comparators, Outcomes, and Timeframes
PMA: Post-Marketing Assessment
QoL: Quality of Life
RCTs: Randomized Controlled Trials
ROB: Risk of Bias
SCEPC: Southern California Evidence-based Practice Center
SD: Standard Deviation
SF-36: Short form-36
SIPS: Scientific Information Packets
SMD: Standardized Mean Difference
SOE: Strength of Evidence
SRC: Scientific Resource Center
TAP: Technology Assessment Program
TKR: Total Knee Replacement
VAS: Visual analog scale
WOMAC: Western Ontario and McMaster Universities Osteoarthritis Index