# References

1 Lawrence RC, Felson DT, Helmick CG, et al. Estimates of the prevalence of arthritis and other rheumatic conditions in the United States. Part II. Arthritis Rheum. Jan. 2008;58(1):26-35. [pmid: 18163497].
2 Dillon CF, Rasch EK, Gu Q, et al. Prevalence of knee osteoarthritis in the United States: arthritis data from the Third National Health and Nutrition Examination Survey 1991-94. J Rheumatol. Nov. 2006;33(11):2271-2279. [pmid: 17013996].
3 Richmond SA, Fukuchi RK, Ezzat A, et al. Are Joint Injury, Sport Activity, Physical Activity, Obesity, or Occupational Activities Predictors for Osteoarthritis? A Systematic Review. J Orthop Sports Phys Ther. 2013. Jun. 11. [pmid: 23756344].
4 Murphy L, Schwartz TA, Helmick CG, et al. Lifetime risk of symptomatic knee osteoarthritis. Arthritis Rheum. Sep. 15. 2008;59(9):1207-1213. [pmid: 18759314].
5 Weinstein AM, Rome BN, Reichmann WM, et al. Estimating the burden of total knee replacement in the United States. J Bone Joint Surg Am. Mar. 6. 2013;95(5):385-392. [pmid: 23344005].
6 Teichtahl AJ, Wluka AE, Wang Y, et al. The longitudinal relationship between changes in body weight and changes in medial tibial cartilage, and pain among community-based adults with and without meniscal tears. Ann Rheum Dis. 2013. Jun. 6. [pmid: 23744978].
7 Schiphof D, de Klerk BM, Kerkhof HJ, et al. Impact of different descriptions of the Kellgren and Lawrence classification criteria on the diagnosis of knee osteoarthritis. Ann Rheum Dis. Aug. 2011;70(8):1422-1427. [pmid: 21555325].
8 Cibere J, Zhang H, Thorne A, et al. Association of clinical findings with pre-radiographic and radiographic knee osteoarthritis in a population-based study. Arthritis Care Res (Hoboken). Dec. 2010;62(12):1691-1698. [pmid: 20665737].
9 Hochberg MC, Altman RD, April KT, et al. American College of Rheumatology 2012 recommendations for the use of nonpharmacologic and pharmacologic therapies in osteoarthritis of the hand, hip, and knee. Arthritis Care Res (Hoboken). Apr. 2012;64(4):465-474. [pmid: 22563589].
10 Fraser JR, Laurent TC, Laurent UB. Hyaluronan: its nature, distribution, functions and turnover. J Intern Med. Jul. 1997;242(1):27-33. [pmid: 9260563].
11 Watterson JR, Esdaile JM. Viscosupplementation: therapeutic mechanisms and clinical potential in osteoarthritis of the knee. J Am Acad Orthop Surg. Sep-Oct. 2000;8(5):277-284. [pmid: 11029555].
12 Bannuru RR, Natov NS, Obadan IE, et al. Therapeutic trajectory of hyaluronic acid versus corticosteroids in the treatment of knee osteoarthritis: a systematic review and meta-analysis. Arthritis Rheum. Dec. 15. 2009;61(12):1704-1711. [pmid: 19950318].
13 Brzusek D, Petron D. Treating knee osteoarthritis with intra-articular hyaluronans. Curr Med Res Opin. Dec. 2008;24(12):3307-3322. [pmid: 18954498].
14 Brander VA, Stadler TS. Functional improvement with hylan G-F 20 in patients with knee osteoarthritis. Phys Sportsmed. Oct. 2009;37(3):38-48. [pmid: 20048527].
15 Lo GH, LaValley M, McAlindon T, et al. Intra-articular hyaluronic acid in treatment of knee osteoarthritis: a meta-analysis. JAMA. Dec. 17. 2003;290(23):3115-3121. [pmid: 14679274].
16 Colen S, van den Bekerom MP, Mulier M, et al. Hyaluronic acid in the treatment of knee osteoarthritis: a systematic review and meta-analysis with emphasis on the efficacy of different products. BioDrugs. Aug. 1. 2012;26(4):257-268. [pmid: 22734561].
17 Rutjes AW, Juni P, da Costa BR, et al. Viscosupplementation for osteoarthritis of the knee: a systematic review and meta-analysis. Ann Intern Med. Aug. 7. 2012;157(3):180-191. [pmid: 22868835].
18 Zhang W, Nuki G, Moskowitz RW, et al. OARSI recommendations for the management of hip and knee osteoarthritis: part III: Changes in evidence following systematic cumulative update of research published through January 2009. Osteoarthritis Cartilage. Apr. 2010;18(4):476-499. [pmid: 20170770].
19 American Academy of Orthopaedic Surgeons. Treatment of Osteoarthritis of the Knee. 2nd Edition: SUMMARY OF RECOMMENDATIONS. http://www.aaos.org/research/guidelines/OAKSummaryofRecommendations.pdf.
20 Bellamy N, Buchanan WW, Goldsmith CH, et al. Validation study of WOMAC: a health status instrument for measuring clinically important patient relevant outcomes to antirheumatic drug therapy in patients with osteoarthritis of the hip or knee. J Rheumatol. Dec. 1988;15(12):1833-1840. [pmid: 3068365].
21 Lequesne MG, Mery C, Samson M, et al. Indexes of severity for osteoarthritis of the hip and knee. Validation--value in comparison with other assessment tests. Scand J Rheumatol Suppl. 1987;65:85-89. [pmid: 3479839].
22 Roos EM, Roos HP, Lohmander LS, et al. Knee Injury and Osteoarthritis Outcome Score (KOOS)--development of a self-administered outcome measure. J Orthop Sports Phys Ther. Aug. 1998;28(2):88-96. [pmid: 9699158].
23 Terwee CB, Coopmans C, Peter WF, et al. Development and Validation of the Computer-Administered Animated Activity Questionnaire to Measure Physical Functioning of Patients With Hip or Knee Osteoarthritis. Phys Ther. 2013. Sep. 12. [pmid: 24029297].
24 Pham T, van der Heijde D, Altman RD, et al. OMERACT-OARSI initiative: Osteoarthritis Research Society International set of responder criteria for osteoarthritis clinical trials revisited. Osteoarthritis Cartilage. May. 2004;12(5):389-399. [pmid: 15094138].
25 RAND Corporation. 36-Item Short Form Survey from the RAND Medical Outcomes Study. RAND Corporation. Accessed on November 6 2013. http://www.rand.org/health/surveys_tools/mos/mos_core_36item.html.
26 Fransen M, Edmonds J. Reliability and validity of the EuroQol in patients with osteoarthritis of the knee. Rheumatology (Oxford). Sep. 1999;38(9):807-813. [pmid: 10515639].
27 Katz S, Ford AB, Moskowitz RW, et al. Studies of Illness in the Aged. The Index of Adl: A Standardized Measure of Biological and Psychosocial Function. JAMA. Sep. 21. 1963;185:914-919. [pmid: 14044222].
28 Lawton MP, Brody EM. Assessment of older people: self-maintaining and instrumental activities of daily living. Gerontologist. Autumn. 1969;9(3):179-186. [pmid: 5349366].
29 Lingard EA, Katz JN, Wright EA, et al. Predicting the outcome of total knee arthroplasty. J Bone Joint Surg Am. Oct. 2004;86-A(10):2179-2186. [pmid: 15466726].
30 Medicare Policies and Guidelines: Viscosupplementation Therapy (L26616). http://www.findacode.com/medicare/policies-guidelines/display-medicare-info.php?type=LCD&type_id=26616&title=viscosupplementation-therapy-l26616.
31 Higgins JP, Altman DG, Gotzsche PC, et al. The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. BMJ. 2011;343:d5928. [pmid: 22008217].
32 Wells GA, Shea B, O'Connell D, et al. The Newcastle-Ottawa Quality Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. 2010.
33 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
34 Shea BJ, Hamel C, Wells GA, et al. AMSTAR is a reliable and valid measurement tool to assess the methodological quality of systematic reviews. J Clin Epidemiol. Oct. 2009;62(10):1013-1020. [pmid: 19230606].
35 Santaguida PL PR. The Development of the McHarm Quality Assessment Scale for adverse events: Delphi Consensus on important criteria for evaluating harms. Available at: http://hiru.mcmaster.ca/epc/mcharm.pdf. 2008.
36 Hedges LV IO. Statistical Methods for Meta-Analysis. San Diego, CA. Inc. AP. 1985.
37 Cornell JE, Mulrow CD, Localio R, et al. Random-Effects Meta-analysis of Inconsistent Effects: A Time for Change. Ann Intern Med. Feb. 18. 2014;160(4). [pmid: 24727843].
38 IntHout J, Ioannidis JP, Borm GF. The Hartung-Knapp-Sidik-Jonkman method for random effects meta-analysis is straightforward and considerably outperforms the standard DerSimonian-Laird method. BMC Med Res Methodol. 2014;14:25. [pmid: 24548571].
39 Begg CB, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. Dec. 1994;50(4):1088-1101. [pmid: 7786990].
40 Egger M, Smith GD, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. British Medical Journal. Sep. 13. 1997;315(7109):629-634. PMID: WOS:A1997XW69400016. [pmid: 9310563].
41 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-560. [pmid: 12958120].
42 Bannuru RR, Schmid CH, Kent DM, et al. Comparative Effectiveness of Pharmacologic Interventions for Knee Osteoarthritis: A Systematic Review and Network Meta-analysis. Annals of Internal Medicine. 2015;162(1):46-54. [pmid: 25560713].
43 Angst F, Aeschlimann A, Stucki G. Smallest detectable and minimal clinically important differences of rehabilitation intervention with their implications for required sample sizes using WOMAC and SF-36 quality of life measurement instruments in patients with osteoarthritis of the lower extremities. Arthritis Rheum. Aug. 2001;45(4):384-391. [pmid: 11501727].
44 Wandel S, Juni P, Tendal B, et al. Effects of glucosamine, chondroitin, or placebo in patients with osteoarthritis of hip or knee: network meta-analysis. BMJ. 2010;341:c4675. [pmid: 20847017].
45 Tubach F, Ravaud P, Martin-Mola E, et al. Minimum clinically important improvement and patient acceptable symptom state in pain and function in rheumatoid arthritis, ankylosing spondylitis, chronic back pain, hand osteoarthritis, and hip and knee osteoarthritis: Results from a prospective multinational study. Arthritis Care Res (Hoboken). Nov. 2012;64(11):1699-1707. [pmid: 22674853].
46 Pham T, Van Der Heijde D, Lassere M, et al. Outcome variables for osteoarthritis clinical trials: The OMERACT-OARSI set of responder criteria. J Rheumatol. Jul. 2003;30(7):1648-1654. [pmid: 12858473].
47 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-523. [pmid: 19595577].
48 Berkman ND, Lohr KN, Ansari M, et al. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville (MD). 2008.
49 Dougados M, Nguyen M, Listrat V, et al. High molecular weight sodium hyaluronate (hyalectin) in osteoarthritis of the knee: a 1 year placebo-controlled trial. Osteoarthritis Cartilage. Apr. 1993;1(2):97-103. [pmid: 8886085].
50 Forster MC, Straw R. A prospective randomised trial comparing intra-articular Hyalgan injection and arthroscopic washout for knee osteoarthritis. Knee. Sep. 2003;10(3):291-293. [pmid: 12893153].
51 Blanco FJ, Fernandez-Sueiro JL, Pinto-Tasende JA, et al. Intra-Articular Hyaluronan Treatment of Patients with Knee Osteoarthritis Waiting for Replacement Surgery. The Open Arthritis Journal. 2008;1:1-7.
52 Barrett JP, Siviero P. Retrospective study of outcomes in hyalgan(R)-treated patients with osteoarthritis of the knee. Clin Drug Investig. 2002;22(2):87-97. [pmid: 23315396].
53 Campbell DG, Angel KR, Dobson PJ, et al. Experiences of viscosupplementation for knee osteoarthritis. Aust Fam Physician. Oct. 2004;33(10):863-864. [pmid: 15532168].
54 Evanich JD, Evanich CJ, Wright MB, et al. Efficacy of intraarticular hyaluronic acid injections in knee osteoarthritis. Clin Orthop Relat Res. Sep. 2001;(390):173-181. [pmid: 11550864].
55 Mazieres B, Bard H, Ligier M, et al. Medicoeconomic evaluation of hyaluronic acid for knee osteoarthritis in everyday practice: the MESSAGE study. Joint Bone Spine. Oct. 2007;74(5):453-460. [pmid: 17921022].
56 Waddell DD, Bricker DC. Total knee replacement delayed with Hylan G-F 20 use in patients with grade IV osteoarthritis. J Manag Care Pharm. Mar. 2007;13(2):113-121. [pmid: 17330972].
57 Whitman CS, Allen D, Comadoll JL, et al. A retrospective study of SUPARTZ and repeat treatment for osteoarthritis pain in the knee. Journal of Managed Care Medicine. 2010;13:43-47.
58 Waddell DD, Joseph B. Delayed Total Knee Replacement with Hylan G-F 20. J Knee Surg. 2014. Oct. 28. [pmid: 25349988].
59 Neustadt DH. Long-term efficacy and safety of intra-articular sodium hyaluronate (Hyalgan) in patients with osteoarthritis of the knee. Clin Exp Rheumatol. May-Jun. 2003;21(3):307-311. [pmid: 12846048].
60 Romero Jurado M, Enrique Fidalgo A, Rodriguez Villar V, et al. Factors related with the time to surgery in waiting-list patients for knee prostheses. Reumatol Clin. May-Jun. 2013;9(3):148-155. [pmid: 23453189].
61 Turajane T, Amphansap T, Labpiboonpong V, et al. Total knee replacement following repeated cycles of intra-articular sodium hyaluronate (500-730 Kda) in failed conservative treatment of knee osteoarthritis: a 54-month follow-up. J Med Assoc Thai. Dec. 2009;92(Suppl 6):S63-S68. [pmid: 20120667].
62 Turajane T, Labpiboonpong V, Maungsiri S. Cost analysis of intra-articular sodium hyaluronate treatment in knee osteoarthritis patients who failed conservative treatment. J Med Assoc Thai. Sep. 2007;90(9):1839-1844. [pmid: 17957928].
63 Turajane T, Tanavaree A, Labpiboonpong V, et al. Outcomes of intra-articular injection of sodium hyaluronate for the treatment of osteoarthritis of the knee. J Med Assoc Thai. Sep. 2007;90(9):1845-1852. [pmid: 17957929].
64 Waddell DD, Bricker DC. Clinical experience with the effectiveness and tolerability of hylan G-F 20 in 1047 patients with osteoarthritis of the knee. J Knee Surg. Jan. 2006;19(1):19-27. [pmid: 16468490].
65 Waddell DD, Cefalu CA, Bricker DC. A second course of hylan G-F 20 for the treatment of osteoarthritic knee pain: 12-month patient follow-up. J Knee Surg. Jan. 2005;18(1):7-15. [pmid: 15742592].
66 Anand A, Balduini F, Rogers K. Hyaluronic acid in management of advanced osteoarthritis of the knee: Retrospective analysis. European Journal of Orthopaedic Surgery and Traumatology. December. 2010;20(8):645-649. FULL TEXT LINK http://dx.doi.org/10.1007/s00590-010-0635-3.
67 Korkmaz M, Erdogan Y, Okur A, et al. Comparison of the effects of intraarticular hyaluronic acid and antiinflammatory drug treatments on the surgical intervention rates in patients with gonarthrosis. Turkish Journal of Medical Sciences. 2013;43(2):222-226. 2013; FULL TEXT LINK http://dx.doi.org/10.3906/sag-1205-122.
68 Dixon AS, Jacoby RK, Berry H, et al. Clinical trial of intra-articular injection of sodium hyaluronate in patients with osteoarthritis of the knee. Curr Med Res Opin. 1988;11(4):205-213. [pmid: 3063436].
69 Altman RD, Moskowitz R. Intraarticular sodium hyaluronate (Hyalgan) in the treatment of patients with osteoarthritis of the knee: a randomized clinical trial. Hyalgan Study Group. J Rheumatol. Nov. 1998;25(11):2203-2212. [pmid: 9818665].
70 Berenbaum F, Grifka J, Cazzaniga S, et al. A randomised, double-blind, controlled trial comparing two intra-articular hyaluronic acid preparations differing by their molecular weight in symptomatic knee osteoarthritis. Ann Rheum Dis. Sep. 2012;71(9):1454-1460. [pmid: 22294639].
71 Brandt KD, Block JA, Michalski JP, et al. Efficacy and safety of intraarticular sodium hyaluronate in knee osteoarthritis. ORTHOVISC Study Group. Clin Orthop Relat Res. Apr. 2001;(385):130-143. [pmid: 11302304].
72 DeCaria JE, Montero-Odasso M, Wolfe D, et al. The effect of intra-articular hyaluronic acid treatment on gait velocity in older knee osteoarthritis patients: a randomized, controlled study. Arch Gerontol Geriatr. Sep-Oct. 2012;55(2):310-315. [pmid: 22169699].
73 Huang TL, Chang CC, Lee CH, et al. Intra-articular injections of sodium hyaluronate (Hyalgan(R)) in osteoarthritis of the knee. a randomized, controlled, double-blind, multicenter trial in the Asian population. BMC Musculoskelet Disord. 2011;12:221. [pmid: 21978211].
74 Huskisson EC, Donnelly S. Hyaluronic acid in the treatment of osteoarthritis of the knee. Rheumatology (Oxford). Jul. 1999;38(7):602-607. [pmid: 10461471].
75 Kahan A, Lleu PL, Salin L. Prospective randomized study comparing the medicoeconomic benefits of Hylan GF-20 vs. conventional treatment in knee osteoarthritis. Joint Bone Spine. Aug. 2003;70(4):276-281. [pmid: 12951310].
76 Karlsson J, Sjogren LS, Lohmander LS. Comparison of two hyaluronan drugs and placebo in patients with knee osteoarthritis. A controlled, randomized, double-blind, parallel-design multicentre study. Rheumatology (Oxford). Nov. 2002;41(11):1240-1248. [pmid: 12421996].
77 Khanasuk Y, Dechmaneenin T, Tanavalee A. Prospective randomized trial comparing the efficacy of single 6-ml injection of hylan G-F 20 and hyaluronic acid for primary knee arthritis: a preliminary study. J Med Assoc Thai. Oct. 2012;95(Suppl 10):S92-S97. [pmid: 23451445].
78 Pavelka K, Uebelhart D. Efficacy evaluation of highly purified intra-articular hyaluronic acid (Sinovial((R))) vs hylan G-F20 (Synvisc((R))) in the treatment of symptomatic knee osteoarthritis. A double-blind, controlled, randomized, parallel-group non-inferiority study. Osteoarthritis Cartilage. Nov. 2011;19(11):1294-1300. [pmid: 21875678].
79 Petrella RJ, DiSilvestro MD, Hildebrand C. Effects of hyaluronate sodium on pain and physical functioning in osteoarthritis of the knee: a randomized, double-blind, placebo-controlled clinical trial. Arch Intern Med. Feb. 11. 2002;162(3):292-298. [pmid: 11822921].
80 Raman R, Dutta A, Day N, et al. Efficacy of Hylan G-F 20 and Sodium Hyaluronate in the treatment of osteoarthritis of the knee -- a prospective randomized clinical trial. Knee. Aug. 2008;15(4):318-324. [pmid: 18430574].
81 Lundsgaard C, Dufour N, Fallentin E, et al. Intra-articular sodium hyaluronate 2 mL versus physiological saline 20 mL versus physiological saline 2 mL for painful knee osteoarthritis: a randomized clinical trial. Scandinavian Journal of Rheumatology. Mar-Apr. 2008;37(2):142-150. PMID: WOS:000255956000011. [pmid: 18415773].
82 Pham T, Le Henanff A, Ravaud P, et al. Evaluation of the symptomatic and structural efficacy of a new hyaluronic acid compound, NRD101, in comparison with diacerein and placebo in a 1 year randomised controlled study in symptomatic knee osteoarthritis. Ann Rheum Dis. Dec. 2004;63(12):1611-1617. [pmid: 15331394].
83 Grecomoro G, Martorana U, Di Marco C. Intra-articular treatment with sodium hyaluronate in gonarthrosis: a controlled clinical trial versus placebo. Pharmatherapeutica. 1987;5(2):137-141. [pmid: 3310017].
84 Henderson EB, Smith EC, Pegley F, et al. Intra-articular injections of 750 kD hyaluronan in the treatment of osteoarthritis: a randomised single centre double-blind placebo-controlled trial of 91 patients demonstrating lack of efficacy. Ann Rheum Dis. Aug. 1994;53(8):529-534. [pmid: 7944639].
85 Roman JA, Chismol J, Morales M, et al. Intra-articular treatment with hyaluronic acid. Comparative study of Hyalgan and Adant. Clin Rheumatol. 2000;19(3):204-206. [pmid: 10870655].
86 Tamir E, Robinson D, Koren R, et al. Intra-articular hyaluronan injections for the treatment of osteoarthritis of the knee: a randomized, double blind, placebo controlled study. Clin Exp Rheumatol. May-Jun. 2001;19(3):265-270. [pmid: 11407078].
87 Leopold SS, Redd BB, Warme WJ, et al. Corticosteroid compared with hyaluronic acid injections for the treatment of osteoarthritis of the knee. A prospective, randomized trial. J Bone Joint Surg Am. Jul. 2003;85-A(7):1197-1203. [pmid: 12851342].
88 Petrella RJ, Cogliano A, Decaria J. Combining two hyaluronic acids in osteoarthritis of the knee: a randomized, double-blind, placebo-controlled trial. Clin Rheumatol. Aug. 2008;27(8):975-981. [pmid: 18204873].
89 Petrella RJ, Decaria J, Petrella MJ. Long term efficacy and safety of a combined low and high molecular weight hyaluronic acid in the treatment of osteoarthritis of the knee. Rheumatology Reports. 2011;3(1):16-21. 2011; FULL TEXT LINK http://dx.doi.org/10.4081/rr.2011.e4.
90 Miller LE, Block JE. US-Approved Intra-Articular Hyaluronic Acid Injections are Safe and Effective in Patients with Knee Osteoarthritis: Systematic Review and Meta-Analysis of Randomized, Saline-Controlled Trials. Clin Med Insights Arthritis Musculoskelet Disord. 2013;6:57-63. [pmid: 24027421].
91 Printz JO, Lee JJ, Knesek M, et al. Conflict of interest in the assessment of hyaluronic acid injections for osteoarthritis of the knee: an updated systematic review. J Arthroplasty. Sep. 2013;28(8 Suppl):30-33 e1. [pmid: 23890521].
92 Trigkilidas D, Anand A. The effectiveness of hyaluronic acid intra-articular injections in managing osteoarthritic knee pain. Ann R Coll Surg Engl. Nov. 2013;95(8):545-551. [pmid: 24165334].
93 Bannuru RR, Vaysbrot EE, Sullivan MC, et al. Relative efficacy of hyaluronic acid in comparison with NSAIDs for knee osteoarthritis: A systematic review and meta-analysis. Seminars in Arthritis and Rheumatism. 2013.
94 Petrella RJ. Hyaluronic acid for the treatment of knee osteoarthritis: long-term outcomes from a naturalistic primary care experience. Am J Phys Med Rehabil. Apr. 2005;84(4):278-283. quiz 84, 93. [pmid: 15785261].
95 Kemper F, Gebhardt U, Meng T, et al. Tolerability and short-term effectiveness of hylan G-F 20 in 4253 patients with osteoarthritis of the knee in clinical practice. Curr Med Res Opin. Aug. 2005;21(8):1261-1269. [pmid: 16083536].
96 Petrella RJ, Cogliano A, Decaria J. Comparison of avian and nonavian hyaluronic acid in osteoarthritis of the knee. Orthopedic Research and Reviews. 2010;2:5-9.
97 Waddell DD, Bricker DC. Hylan G-F 20 tolerability with repeat treatment in a large orthopedic practice: a retrospective review. J Surg Orthop Adv. Spring. 2006;15(1):53-59. [pmid: 16603113].
98 Pullman-Mooar S, Mooar P, Sieck M, et al. Are there distinctive inflammatory flares after hylan g-f 20 intraarticular injections?. J Rheumatol. Dec. 2002;29(12):2611-2614. [pmid: 12465161].
99 Roos J, Epaulard O, Juvin R, et al. Acute pseudoseptic arthritis after intraarticular sodium hyaluronan. Joint Bone Spine. Jul. 2004;71(4):352-354. [pmid: 15288866].
100 Tahiri L, Benbouazza K, Amine B, et al. Acute pseudoseptic arthritis after viscosupplementation of the knee: a case report. Clin Rheumatol. Nov. 2007;26(11):1977-1979. [pmid: 17436053].
101 Idrissi Z, Benbouazza K, Fourtassi M, et al. Acute pseudo-septic arthritis following viscosuplementation of the knee. Pan Afr Med J. 2012;12:44. [pmid: 22937184].
102 Bernardeau C, Bucki B, Liote F. Acute arthritis after intra-articular hyaluronate injection: onset of effusions without crystal. Ann Rheum Dis. May. 2001;60(5):518-520. [pmid: 11302877].
103 Maillefert JF, Hirschhorn P, Pascaud F, et al. Acute attack of chondrocalcinosis after an intraarticular injection of hyaluronan. Rev Rhum Engl Ed. Oct. 1997;64(10):593-594. [pmid: 9385702].
104 Wendling D, Royer F, Chabroux A, et al. Acute gouty arthritis after intraarticular hyaluronate injection. Joint Bone Spine. Dec. 2007;74(6):664-665. [pmid: 17900963].
105 Ali Y, Weinstein M, Jokl P. Acute pseudogout following intra-articular injection of high molecular weight hyaluronic acid [2]. American Journal of Medicine. 1999;107(6):641-642. 1999; MEDLINE PMID 10625037 (http://www.ncbi.nlm.nih.gov/pubmed/10625037) FULL TEXT LINK http://dx.doi.org/10.1016/S0002-9343(99)00255-7. [pmid: 10625037].
106 Kunugiza Y, Tani M, Tomita T, et al. Staphylococcal scalded skin syndrome after intra-articular injection of hyaluronic acid. Mod Rheumatol. Jun. 2011;21(3):316-319. [pmid: 21188450].
107 Lequerre T, Nouvellon M, Kraznowska K, et al. Septic arthritis due to Actinomyces naeslundii: report of a case. Joint Bone Spine. Oct. 2002;69(5):499-501. [pmid: 12477236].
108 Shemesh S, Heller S, Salai M, et al. Septic arthritis of the knee following intraarticular injections in elderly patients: report of six patients. Isr Med Assoc J. Dec. 2011;13(12):757-760. [pmid: 22332447].
109 Iizuka M, Yao R, Wainapel S. Saphenous nerve injury following medial knee joint injection: a case report. Arch Phys Med Rehabil. Oct. 2005;86(10):2062-2065. [pmid: 16213255].
110 Martens PB. Bilateral symmetric inflammatory reaction to hylan G-F 20 injection. Arthritis Rheum. Apr. 2001;44(4):978-979. [pmid: 11315938].
111 Rees JD, Wojtulewski JA. Systemic reaction to viscosupplementation for knee osteoarthritis. Rheumatology (Oxford). Dec. 2001;40(12):1425-1426. [pmid: 11752524].
112 Banerjee M. Eosinophiluria from intra-articular hyaluronic acid injection. Clinical and Experimental Nephrology. Dec. 2002;6(4):248-249. FULL TEXT LINK http://dx.doi.org/10.1007/s101570200042.
113 Semih T, Bilgen O, Cemile E, et al. Herpes zoster development after intraarticular sodium hyaluronate injection. Journal of Musculoskeletal Pain. February. 2009;17(1):86-89. FULL TEXT LINK http://dx.doi.org/10.1080/10582450802679797.
114 Calvo M, Tornero P, De Barrio M, et al. Erytema multiform due to hyaluronic acid (Go-On). Journal of Investigational Allergology and Clinical Immunology. 2007;17(2):127-128. PMID: WOS:000246236700012. [pmid: 17460954].
115 Michou L, Job-Deslandre C, de Pinieux G, et al. Granulomatous synovitis after intraarticular Hylan GF-20. A report of two cases. Joint Bone Spine. Sep. 2004;71(5):438-440. [pmid: 15474399].
116 Bannuru RR, Natov NS, Dasi UR, et al. Therapeutic trajectory following intra-articular hyaluronic acid injection in knee osteoarthritis--meta-analysis. Osteoarthritis Cartilage. Jun. 2011;19(6):611-619. [pmid: 21443958].
117 Mandl LA, Losina E. Relative efficacy of knee osteoarthritis treatments: are all placebos created equal?. Ann Intern Med. Jan. 6. 2015;162(1):71-72. [pmid: 25560716].
118 Bannuru RR, Vaysbrot EE, McIntyre LF. Did the American Academy of Orthopaedic Surgeons osteoarthritis guidelines miss the mark?. Arthroscopy. Jan. 2014;30(1):86-89. [pmid: 24384274].
119 Do Hyaluronic Acid Injections Delay Total Knee Replacement Surgery?. Abstract:#2139. 2013. October. 29.
120 Dasa V, DeKowen M, Lim S, Long K, Heeckt P. M12. Effectiveness of Repeated Courses of Hyaluronic Acid Injections on the Time to Total Knee Replacement Surgery: Evidence from a Large U.S. Health Plan Claims Database. Academy of Managed Care Pharmacy 2014 Nexus; 2014 October 7-10; Boston, Massachusetts. Journal of Managed Care and Specialty Pharmacy. 20:10-A. s53.
121 Khan T, Nanchanatt G, Jan SA, Farber K. M10. Analysis of the Effectiveness of Hyaluronic Acid in Prevention of Knee Surgery in Osteoarthritis Patients 26th Annual Meeting and Exp 2014 Tampa, Florida. Journal of Managed Care and Specialty Pharmacy. 20:4-A. S49.
122 Maillefert JF, Hawker GA, Gossec L, et al. Concomitant therapy: an outcome variable for musculoskeletal disorders? Part 2: total joint replacement in osteoarthritis trials. J Rheumatol. Dec. 2005;32(12):2449-2451. [pmid: 16331784].
123 Smith SM, Wang AT, Katz NP, et al. Adverse event assessment, analysis, and reporting in recent published analgesic clinical trials: ACTTION systematic review and recommendations. Pain. Jul. 2013;154(7):997-1008. [pmid: 23602344].