# Appendices

Appendix A Search Strategy

Appendix B List of Excluded Studies

Appendix C Evidence Table

Appendix D Data Abstraction Tools

Appendix E Non-English Language Article Abstracts Reviewed

Appendix F Non-US Approved HA Devices

Appendix G Strength of Evidence Assessment Required Domains: Definitions and Scores

Appendix H Tools to Measure Function