# Methods

The methods for this Technology Assessment follow the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews.17

## Protocol Development

Representatives from the Coverage and Analysis Group at CMS posed the questions for this review. With feedback from these representatives, from AHRQ representatives and from our key informants, we refined these questions and developed a protocol for this systematic review. Our protocol was registered on PROSPERO (CRD42014009981).

## Search Strategy

We searched MEDLINE, Embase®, and the Cochrane Central Register of Controlled Trials (CENTRAL) from January 1, 1995, as this is the date of first article reporting use of CRT through October 20th, 2014. We developed a search strategy based on medical subject headings (MeSH®) terms and text words of key articles (Appendix B). We also reviewed the reference lists of all included articles. In addition, we requested Scientific Information Packets from device manufacturers (Table 3). We had no language restrictions in the search strategies. Additionally, on January 22nd, 2015, we searched Clinicaltrials.gov to identify relevant registered trials.

## Study Selection

Study selection was based on predefined eligibility criteria of patient populations, interventions, outcome measures, and study design (see Table 1 and 2). Abstracts were screened independently by two reviewers, and were excluded if both reviewers agreed that one or more of the exclusion criteria was met (see Appendix C Abstract Screen Form). Differences between reviewers regarding abstract eligibility were resolved through consensus. We used DistillerSR (Evidence Partners, 2010) to manage the screening process.

Citations promoted on the basis of the abstract screen underwent another independent screen using the full-text of the articles. Additional exclusion criteria were applied at this level (see Table 2 and Appendix C Article Screen Form). Differences regarding citation eligibility were resolved through consensus.

## Data Abstraction and Data Management

We created and pilot tested data extraction forms in Excel (Microsoft, Redmond, WA) (Appendix C). Reviewers extracted information on general study characteristics (e.g., study design, study period, and followup), study participants (e.g., age, gender, race/ethnicity, etc.), eligibility criteria, interventions, outcome measures and the method of ascertainment, and the results of each outcome, including measures of variability. Data when available by subgroups (females, QRS duration >150 ms, left bundle branch block, atrial fibrillation and non-ischemic cardiac conditions) were also abstracted. For studies reporting patient data, including outcomes, undifferentiated as to CRT-D or CRT-P we contacted the authors for clarification and data (see Data Synthesis).

One reviewer completed data abstraction and a second reviewer checked the first reviewer’s abstraction for completeness and accuracy. We resolved differences between reviewer pairs through discussion and, as needed, through consensus among our team.

Table 1 PICOTS (population, interventions, comparators, outcomes, timing, setting) for each Key Question

| Effectiveness KQ1a: CRT-D KQ3a: CRT-P KQ5: CRT-D vs CRT-P | Harms KQ2: CRT-D KQ4: CRT-P KQ6: CRT-D vs CRT-P | Clinical predictors KQ1b: CRT-D KQ 2b: CRT-P
Population | - Age ≥ 18; - Subjects with a left ventricular ejection fraction ≤35% and a QRS duration ≥120 ms.
Interventions | - Cardiac resynchronization therapy with a defibrillator (CRT-D); - Cardiac resynchronization without a defibrillator (CRT-P) | - Cardiac resynchronization therapy with a defibrillator (CRT-D); - Cardiac resynchronization without a defibrillator (CRT-P) | - Cardiac resynchronization therapy with a defibrillator (CRT-D); - Cardiac resynchronization without a defibrillator (CRT-P)
Comparisons | - CRT-D: Implantable Cardioverter Defibrillator (ICD); - CRT-P: Optimal medical therapy; - CRT-D versus CRT-P | - CRT-D: Implantable Cardioverter Defibrillator (ICD); - CRT-P: Optimal medical therapy; - CRT-D versus CRT-P | - CRT-D: Implantable Cardioverter Defibrillator (ICD); - CRT-P: Optimal medical therapy
Outcomes | - 6 minute hall walk distance; - Minnesota Living with Heart Failure Questionnaire; - SF-36; - Left ventricular end systolic volume/volume index; - Left ventricular end diastolic volume/volume index; - Left ventricular ejection fraction; - Clinical composite score (Packer Score); - Hospitalizations for heart failure; - All- cause mortality | - Procedure related complications; - Length of hospital stay; - Pneumothorax; - Pocket hematoma; - Device Infection; - Cardiac perforation/tamponade; - Lead dislodgement; - Ventricular arrhythmias; - Inappropriate ICD shocks (CRT-D only); - Death (within a week) | - Age; - Gender; - Cardiomyopathy subtype; - History of atrial fibrillation; - QRS duration; - QRS morphology; - Chronic kidney disease; - Left atrial volume; - Left ventricular ejection fraction; - Body mass index; - Baseline left ventricular end diastolic volume
Type of study | Randomized controlled trials | Any study design except case report | Any study design except case report
Timing and setting | CRT-D and CRT-P at 3–6 months, 1 year, and ≥2 year end-points KQ2,4 and 6 (harms) Outcomes (above) from CRT-D and CRT-P at any time point | Any time point | Any time point

Table 2 List of exclusion criteria at the abstract and article screening level

| Abstract screening level | Article screening level
Exclusion criteria | - Does not evaluate CRT; - Study published before 1995; - No original data (systematic reviews, meta-analysis, editorial, commentary); - Not conducted in humans; - Not in English; - No full report (e.g. conference or meeting abstract); - Study of children only; - Not relevant to key questions | - Does not evaluate CRT; - Study published before 1995; - No original data (systematic reviews, meta-analysis, editorial, commentary); - Not conducted in humans; - Not in English; - No full report (e.g. conference or meeting abstract); - Study of children only; - Not relevant to key questions.
Additional exclusion criteria at the article screening level | | - Single case study; - Addresses effectiveness questions (KQ1a, 3a, and 5) only and is not RCT; - Population inclusion criteria do not fall within the QRS duration ≥120ms range and LVEF≤35%; - Address remodeling outcomes but response definition not within range of LVESV≥10%, LVEDV ≥10% or EF≥5%; - Study does not adjust via model or participant selection for at least 2 predictor of gender, QRS duration and/or morphology (LBB or not ) and does not include at least 30 patients

Table 3 List of CRT device manufacturers

Manufacturer | Device
Boston Scientific | COGNIS® CRT-D
| ENERGEN™ CRT-D
| INCEPTA™ CRT-D
| PUNCTUA™ CRT-D
| INVIVE™ CRT-P
BIOTRONIK | Lumax 300 HF-T CRT-D
| Lumax 340 HF-T CRT-D
| Lumax 540 HF-T CRT-D
| Stratos LV-T CRT-P
| Evia HFT-T CRT-P
Medtronic | Viva™ XT CRT-D
| Viva™ S CRT-D
| Protecta® XT CRT-D
| Protecta® CRT-D
| Consulta® CRT-D
| Concerto® II CRT-D
| Maximo® II CRT-D
| InSync Sentry® CRT-D
| InSync II™ Marquis CRT-D
| InSync III® CRT-P
| Consulta® CRT-P
| Syncra™ CRT-P
St. Jude Medical | Promote™ Plus CRT-D
| Quadra Assura™ CRT-D
| Unify Assura™ CRT-D
| Unify Quadra™ CRT-D
| Unify™ CRT-D
| Anthem™ CRT-P
SORIN GROUP | PARADYM™ CRT
| Paradym™ RF SonR® CRT-D
| Paradym™ RF CRT-D

## Risk of Bias Assessment

Two reviewers independently assessed risk of bias for individual studies. We used the Cochrane Collaboration’s tool for assessing the risk of bias of controlled studies.18 For nonrandomized studies, we used the Newcastle Ottawa Scale 19 and for predictor studies, we used Quality In Prognosis Studies (QUIPS) tool.20 Differences between reviewers were resolved through consensus.

## Data Synthesis

For each key question, we created a detailed set of evidence tables containing all information abstracted from eligible studies. We followed these steps for studies which reported data for both devices (CRT-D and CRT-P) in one arm or group or for which the type of device was unclear:

1. If the type of device is not specified, we contacted the study authors to request information about type of device.
2. If the number of patients receiving each device is not specified, we contacted the study authors to request information about the number of patients receiving each device.
3. If the number of patients receiving each device is not specified, and the outcomes are not presented separately, we contacted the study author to request device-specific outcome data.
4. If the number of patients receiving each device is specified, but the outcomes are not presented separately, we attributed the reported outcomes to the device received by ≥ 90 percent of the patients.
5. If the number of patients receiving each device is specified and the outcomes are not presented separately and no more than 90 percent of the patients received any one type of device or all devices were received by an equal number of patients, we contacted the study authors to request device-specific outcome data.

All studies were summarized qualitatively. We conducted meta-analyses for an outcome when there were sufficient data (at least 3 studies of the same design) and studies were sufficiently homogenous with respect to key variables (population characteristics, intervention, and outcome measurement) using profile likelihood estimate for random effects model. We identified substantial statistical heterogeneity in the trials as an I-squared statistic with a value greater than 50 percent. We planned to assess publication bias using Begg‘s and Eggers tests (with alpha of 0.10) including evaluation of the asymmetry of funnel plots for each comparison of interest for the outcomes where meta-analyses are conducted. Criteria for testing for funnel plot asymmetry was at least 10 studies of unequal sizes contributing quantitative data for which there is no apparent relationship between study size and between study clinical or methodological diversity. All meta-analyses were conducted using STATA 12.1 (College Station, TX).

## Strength of the Body of Evidence

We graded the strength of evidence using the scheme recommended by the AHRQ EPC Methods Guide for Conducting Comparative Effectiveness Reviews.21 For this report, we graded the strength of evidence for the outcomes we classified during protocol development as the most important or critical outcomes, including quality of life as assessed by the Minnesota Living with Heart Failure Questionnaire, left ventricular end systolic volume, hospitalizations for heart failure and, all- cause mortality. We considered five domains: study limitations, directness, consistency, precision, and reporting bias. We classified evidence pertaining to the KQs into four basic categories: 1) “high” grade; 2) “moderate” grade; 3) “low” grade; and 4) “insufficient” grade (Table 4).

Investigators writing each section completed the strength of evidence grading. The team members reviewed grading and discussed the process they used to grade the evidence throughout the report writing process.

Table 4 Strength of evidence grades and definitions

Grade | Definition
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable.
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding judgment.

## Applicability

Applicability was assessed separately for the different outcomes for the entire body of evidence guided by the PICOS framework as recommended in the Methods Guide for Comparative Effectiveness Reviews of Interventions.17 We considered important population characteristics (e.g., gender, race, ethnicity), comorbidities (e.g. atrial fibrillation, bundle branch pathologies), and intervention (e.g. therapy, co-intervention) that may cause heterogeneity of treatment effects and effect generalizability of the findings.

## Peer Review and Public Comment

The draft report was peer reviewed and posted for public comment from November 27^th^, 2014, through December 11^th^, 2014. Comments received from invited reviewers and through the public comment website were compiled and addressed. A disposition of comments will be posted on the AHRQ Web site 3 months after the release of the final technology assessment.