# Introduction

Chronic heart failure (CHF) is a major public health problem in the United States affecting an estimated 4.9 million Americans, with 550,000 new cases diagnosed annually.1 CHF patients have high rates of hospitalization, poor quality of life, and account for 300,000 deaths in the United States each year.1 The annual cost of CHF in 2010 was estimated at $39.2 billion or approximately 2 percent of the total United States healthcare budget.2 Targeted interventions for this commonly encountered condition are needed, aimed at improving quality of life, reducing hospitalizations, and decreasing mortality.

Left ventricular (LV) activation delay, as approximated by widening of the QRS complex on a twelve lead electrocardiogram, is present in approximately one-quarter to one-third of heart failure patients. Such delay leads to inefficient myocardial hemodynamics, which may impair cardiac function further. Cardiac resynchronization (CRT) is a pacing modality utilizing an LV pacing lead with the goal of re-synchronizing myocardial contraction in patients with CHF, depressed systolic function, and significant LV activation delay. CRT is thought to produce a reduction in intraventricular dyssynchrony and more favorable hemodynamics by placement of a pacing lead, either endovascularly via a coronary sinus tributary, or epicardially with direct placement on the lateral LV wall via a thoracotomy. CRT was originally indicated in patients with significant LV dysfunction, defined as a left ventricular ejection fraction (LVEF) ≤ 35%, with New York Heart Association (NYHA) class III–IV heart failure symptoms, and with a QRS duration ≥120ms on optimal medical therapy.3–5 More recently, the indications for CRT expanded to include patients with less advanced heart failure.6, 7 In addition, the most recent guidelines for CRT implantation have called to attention the importance of both QRS duration and morphology.1

Multiple large scale clinical trials have been conducted to assess the effects of CRT. Early trials of CRT compared CRT pacemakers with optimal medical therapy alone in patients with advanced CHF.3, 5, 8 With the concomitant development of the implantable cardiac defibrillator (ICD), comparisons used in the large clinical trials changed to compare patients with ICDs with and without CRT.6, 7 Currently, the vast majority of candidates for CRT devices also have an indication for an ICD; therefore, the large majority of patients receiving CRT in the United States receive a CRT defibrillator (CRT-D) as opposed to a CRT pacemaker (CRT-P). CRT-P devices are occasionally placed in patients who wish to avoid ICD shocks (such as in the geriatric population who may be more interested in quality of life compared to life prolongation) or in patients with an indication for frequent right ventricular pacing due to conduction disease who have an LVEF between 36–50 percent.

The early trials of CRT focused on “softer” or more subjective endpoints including changes in quality of life scores, NYHA functional class, and six minute hall walk distances.3, 8 More objective or “harder” endpoints were included in subsequent studies including ventricular remodeling, myocardial oxygen consumption, CHF hospital admissions, and all-cause mortality.4, 7 CRT has been one of the most important therapeutics for the treatment of CHF over the past 20 years, but not every patient who meets the guideline criteria for CRT appears to respond to this therapy. While the percentage of “non-responders” to CRT fluctuates greatly primarily based on how one defines “response”, it is generally estimated that between 30–40 percent of patients receiving CRT derive what may appear to be little benefit.9 Prediction of response to CRT is an important goal in order to tailor this therapy to patients most apt to derive benefit.9 In addition, the specter of patient harm in certain subgroups has been raised.10

The impact of bundle branch block morphology and duration on patient outcomes receiving CRT devices continues to be an important area of research.11–13 The new 2013 United States guidelines for the implantation of CRT capable devices take both bundle branch block morphology and QRS duration into consideration in determining appropriateness for CRT device implantation.14, 15 It is not yet clear how these new guidelines may impact response rates, but any improvement is expected to be incremental, with the issue of non-responders not completely resolved. Not all potential causes of non-response were considered in the new guidelines.16

## Scope and Key Questions

We conducted a systematic review on the efficacy for both CRT-D and CRT-P. The questions were nominated for the Agency for Healthcare Research and Quality (AHRQ) Evidence-based Practice Center (EPC) Program by the Centers for Medicare and Medicaid (CMS) and thus focus on the Medicare population. We developed analytic frameworks to illustrate the different questions and outcomes we considered (Figures 1, 2 and 3). We sought to address the following Key Questions (KQ):

KQ1a: Is cardiac resynchronization therapy with defibrillator (CRT-D) effective in reducing heart failure symptoms, improving myocardial function, reducing hospitalization and/or improving survival in patients with an LVEF≤35% and a QRS duration≥120ms?

KQ1b: What are the clinical predictors of response in Medicare eligible patients who are deemed appropriate candidates for CRT-D devices?

KQ2: What are the adverse effects or complications associated with CRT-D implantation in the Medicare population?

KQ3a: Is cardiac resynchronization therapy in the absence of defibrillator capacity (CRT-P) effective in reducing heart failure symptoms, improving myocardial function, reducing hospitalization and/or improving survival in patients with LVEF≤35% and a QRS duration≥120ms?

KQ3b: What are the clinical predictors of response in Medicare eligible patients who are deemed appropriate candidates for CRT-P devices?

KQ4: What are the adverse effects or complications associated with CRT-P implantation in the Medicare population?

KQ5: What is the effectiveness of CRT-D versus CRT-P in reducing heart failure symptoms, improving myocardial function, reducing hospitalization and/or improving survival in patients with LVEF≤35% and a QRS duration≥120ms?

KQ6: What are the adverse effects or complications associated with CRT-D versus CRT-P implantation in the Medicare population?

Figure 1 Analytic framework for use of cardiac resynchronization therapy with defibrillator (CRT-D) in the Medicare population

Figure 1 is our preliminary analytic framework which describes the key questions 1 and 2. Moving from left to right, there are text, arrows, boxes, and circles that have text within and around. The first thing on the left shows the intervention, which is cardiac resynchronization therapy with defibrillator (CRT-D). There is an arrow pointing to intermediate outcomes of the intervention denoting KQ1. The intermediate outcomes include 6 minute hall walk distance, Minnesota Living with Heart Failure Inventory score, left ventricular end diastolic volume, left ventricular end systolic volume, left ventricular ejection fraction, and clinical composite score (Packer Score). There is another arrow pointing from this to another box which is also part of KQ1 and it describes health outcomes (re- hospitalizations for heart failure and all- cause mortality) of the intervention CRT-D. There is also an arrow that points down to a circle labeled adverse effects of intervention which denotes KQ2. The adverse effects include procedure related complications, length of hospital stay, pneumothorax, pocket hematoma, device infection, cardiac perforation/tamponade, lead dislodgement, ventricular arrhythmias and inappropriate ICD shocks.

Figure 2 Analytic framework for use of cardiac resynchronization therapy without defibrillator capacity (CRT-P) in the Medicare population

Figure 2 is our preliminary analytic framework which describes the key questions 3 and 4. Moving from left to right, there is text, arrows, boxes, and circles that have text within and around. The first thing on the left shows the intervention, which is cardiac resynchronization therapy without defibrillator (CRT-P). There is an arrow pointing to intermediate outcomes of the intervention denoting KQ3. The intermediate outcomes include 6 minute hall walk distance, Minnesota Living with Heart Failure Inventory score, left ventricular end diastolic volume, left ventricular end systolic volume, left ventricular ejection fraction, and clinical composite score (Packer Score). There is another arrow pointing from this to another box which is also part of KQ3 and it describes health outcomes (re- hospitalizations for heart failure and all- cause mortality) of the intervention CRT-P. There is also an arrow that points down to a circle labeled adverse effects of intervention which denotes KQ4. The adverse effects include procedure related complications, length of hospital stay, pneumothorax, pocket hematoma, device infection, cardiac perforation/tamponade, lead dislodgement, ventricular arrhythmias and inappropriate shocks.

Figure 3 Analytic framework for use of cardiac resynchronization therapy with defibrillator capacity (CRT-D) versus cardiac resynchronization therapy without defibrillator capacity (CRT-P) in the Medicare population

Figure 3 is our preliminary analytic framework which describes the key questions 5 and 6. Moving from left to right, there is text, arrows, boxes, and circles that have text within and around. The first thing on the left shows the comparisons of interventions, cardiac resynchronization therapy with defibrillator (CRT-D) versus cardiac resynchronization therapy without defibrillator (CRT-P). There is an arrow pointing to intermediate outcomes of the intervention denoting KQ5. The intermediate outcomes include 6 minute hall walk distance, Minnesota Living with Heart Failure Inventory score, left ventricular end diastolic volume, left ventricular end systolic volume, left ventricular ejection fraction, and clinical composite score (Packer Score). There is another arrow pointing from this to another box which is also part of KQ5 and it describes health outcomes (re- hospitalizations for heart failure and all- cause mortality) of the intervention CRT-D versus CRT-P. There is also an arrow that points down to a circle labeled adverse effects of intervention which denotes KQ6. The adverse effects include procedure related complications, length of hospital stay, pneumothorax, pocket hematoma, device infection, cardiac perforation/tamponade, lead dislodgement, ventricular arrhythmias and inappropriate shocks.