# Discussion

## Key Findings and the Strength of Evidence

### Efficacy and Safety of CRT-D (KQ1a, KQ2)

There is convincing evidence that CRT-D devices are effective in reducing heart failure symptoms, improving myocardial function, and reducing hospitalizations for heart failure in patients with an LVEF≤35% and a QRS duration ≥120 ms compared to therapy with an ICD alone. Specifically, we found moderate strength of evidence for benefit of CRT-D versus ICD alone for all-cause mortality in minimally symptomatic patients. This statement is derived from data looking primarily at NYHA class II patients. The applicability of this finding to NYHA class I patients, a population significantly under-represented in studies, is unclear. There is insufficient evidence to determine whether CRT-D devices are effective in improving survival compared to an ICD alone in an advanced heart failure population (NYHA III–IV).(Table 60)

In terms of pre-specified subgroups, there is compelling evidence that in CRT-D patients (compared to an ICD alone), female gender, a left bundle branch block, and non-ischemic cardiomyopathy are associated with superior outcomes. Sinus rhythm (as opposed to a history of atrial fibrillation) and a wider QRS complex and also associated with superior outcomes in patients undergoing CRT-D implant compared to an ICD alone although the data for this are less compelling.

Prevalence of harms associated with CRT-D devices were as follows: cardiac perforation/tamponade (0.1–1.4%), pocket hematoma (0.9–2.8%), pneumothorax (1.3–2.8%), device infection (0.9–2.8%), and lead dislodgement (2.4% to 9.8%). No conclusions could be drawn about the association between CRT-D implant and both ventricular arrhythmias and inappropriate shocks. Death within one week of implantation was 0 percent although only two studies reported this outcome.

### Efficacy and Safety of CRT-P (KQ3a, KQ4)

There is moderate evidence that CRT-P, compared to optimal medical therapy, is effective in improving survival, reducing LESV, and reducing hospitalizations for heart failure in patients with an LVEF≤35% and a QRS duration ≥120 ms compared to optimal medical therapy alone. These data are largely derived from patients with NYHA class III–IV heart failure. The applicability of these findings to patient with NYHA class I–II heart failure is unclear. We found insufficient evidence about the effect of CRT-P on quality of life as measured with the MLHFQ.

Harms associated with CRT-P were as follows: cardiac perforation/tamponade (0–1.6%), pocket hematoma (0.2–9.5%), pneumothorax (0.5–1.5%), device infection (0.7–4.8%), and lead dislodgement (1.7–17%). Death within one week of implantation was reported in only very small studies making the true incidence unclear.

### Efficacy and Safety of CRT-D versus CRT-P (KQ5, KQ6)

Only one included trial contained both CRT-D and CRT-P arms, and direct comparisons between those arms were lacking. Therefore there is insufficient evidence to determine the effectiveness of CRT-D compared to CRT-P. In comparing harms between CRT-D and CRT-P devices, there was also insufficient evidence to draw any conclusions except for device infections, which appear to be slightly more common for CRT-D devices.

### Predictors of Response: CRT-D and CRT-P (KQ1b, KQ3b)

The evidence regarding predictors of a favorable response following CRT varied considerably based on outcome. In addition, the high likelihood of reporting bias qualifies these results. Age was not an important predictor of outcomes in patients receiving CRT-D devices. However, data for very elderly patients (> 75 years of age) was limited. Non-ischemic cardiomyopathy, female gender, and a left bundle branch block morphology were strongly associated with improved outcomes. A history of atrial fibrillation and a narrower QRS duration were associated with poorer outcomes although the evidence for this was less robust. There was insufficient data to determine the predictive nature of chronic kidney disease, left atrial volume, baseline LVEF, body mass index, and left ventricular end-diastolic volume on outcomes following CRT-D implant. There was also insufficient evidence to draw conclusions as to the predictive nature of baseline characteristics and outcomes in patients receiving a CRT-P device. However, of the outcomes that were assessed, the ICD function would impact only the mortality endpoint. Therefore similar conclusions as to those noted for CRT-D can likely be drawn for CRT-P devices for the other, non-mortality endpoints (Table 60).

Table 60 Summary of the strength of evidence for key effectiveness outcomes

Comparisons | All-cause mortality | Hospitalizations for heart failure | Left ventricular end systolic volume (or index) | Minnesota Living with Heart Failure Questionnaire
Cardiac resynchronization therapy with defibrillator (CRT-D) vs. ICD alone | Moderate In patients with minimally symptomatic CHF (primarily class NYHA class II), data from the RAFT trial (a larger, slightly more symptomatic population, with a longer followup) demonstrates a mortality benefit, The MADIT-CRT trial did not report a mortality benefit with CRT-D in primarily NYHA class II patients. Long-term followup of a subset of patients demonstrated a mortality benefit in patients with LBBB but not with a non-LBBB and did not report a mortality comparison for the group as a whole. The other trials assessing mortality in minimally symptomatic patients were either too small in size or followup to add significant additional evidence. The trials assessing mortality in patients with NYHA class III–IV symptoms were limited in terms of followup and size, therefore there is insufficient evidence to determine the effect of CRT-D on mortality compared to an ICD alone. | High The large RAFT and MADIT-CRT trials showed a reduction in CHF events for CRT-D compared to an ICD alone. Subgroup analyses from both trials demonstrate the effect to be primarily in patients with an LBBB morphology | High The trials were consistent in demonstrating a reduction in LVESV with CRT-D compared to an ICD alone. Meta-analysis of trials in patients with NYHA I–II (primarily NYHA class II patients), mean difference −22.55 (95% CI, −40.66 to −9.56). | High The current data suggest that CRT-D does not improve QOL in minimally symptomatic patients compared to an ICD alone. The data does suggest a significant improvement in QOL in patients with NYHA class III–IV CHF (mean difference −10.91 (95% CI −12.03 to 7.27).
Cardiac resynchronization therapy with pacemaker vs. optimal medical therapy | Moderate Studies showed statistically significant differences in mortality favoring CRT-P | Moderate Studies showed fewer hospitalizations in the CRT-P group | Low CRT-P significantly reduced LESV compared with optimal medical therapy. | Insufficient
cardiac resynchronization therapy with pacemaker or with defibrillator | Insufficient | Low Compared with optimal medical therapy, CRT-P and CRT-D were associated with 44% and 41% reduction in heart failure hospitalizations (not significantly different). | Insufficient | Insufficient

## Relationship of Findings to Existing Literature

Several systematic reviews have focused on CRT but none has performed a comprehensive assessment of predictors of outcomes following CRT (see Table 61). Our current review also differs from prior reviews in that only studies with patients with an LVEF≤35% and a baseline QRS duration≥120 ms undergoing biventricular pacing were included. These criteria were developed in consultation with our key informants and largely mirror the current appropriate use criteria for CRT based on guidelines.1 This eliminated the REVERSE, BLOCK-HF, and HOBIPACE trials which included patients with LVEFs >35%.102–104 In addition, all trials looking at the effects of CRT in a narrow QRS population,105–107 and studies of LV only pacing were excluded.108, 109 We considered the appropriate control for the CRT-D effectiveness question to be an ICD alone given the compelling data demonstrating improvements in mortality with an ICD that evolved concomitantly with studies of CRT effectiveness. We considered the appropriate control and for CRT-P to be optimal medical therapy alone to assess the impact of cardiac resynchronization. We did not assess the comparison of CRT-D to optimal medical therapy as we determined this to be an inappropriate comparison, given the known improvements in mortality by defibrillation. Also, in contrast to several previous reviews, we included only RCTs to assess the key questions regarding effectiveness.

In terms of minimally symptomatic patients, the results of our review largely agree with those of prior reviews, which focused on the same population. Similarly, the current review is in agreement with the systematic review performed in 2007 by Mcallister et al., which included studies primarily involving an advanced heart failure population.110 Our review arrived at somewhat different conclusions in terms of the efficacy of CRT-D vs. CRT-P compared to that by Jiang et al.111 Given that we considered only RCTs for determination of effectiveness, only the COMPANION trial was included in our review, which likely explains the discrepancy in conclusions.4

In our systematic analysis of predictors of outcomes following CRT, many studies assessing the capacity for baseline characteristics to predict responses (defined in many different ways) were identified. The large majority of studies were small (<100 patients) and not properly controlled. At a minimum, we pre-specified that a cohort study address our questions about predictors of response to CRT had to include at least gender and either QRS duration or morphology in a multivariate model to address confounding. Such criteria eliminated many studies. Despite this, the positive predictive effect noted with LBBB, female gender, non-ischemic cardiomyopathy, a wider QRS duration, and normal sinus rhythm on multiple outcomes was supportive of the similar findings noted from the pre-specified subgroup analyses of the RCTs. There are other potential predictors we did not consider (e.g. lead position). Given the large number of potential predictors in the literature, a review of all predictors was not practical. Our predictors were chosen based on prevailing knowledge of the most important predictors, identified in consultation with our key informants.

Finally, we did not conduct individual patient data meta-analysis to assess predictors meaning that our analyses may suggest that clinically relevant subgroup effects exist, but we are unable to quantify the effects reliably or precisely.

Table 61 Prior Systematic Reviews of Cardiac Resynchronization Therapy

Author, year | Review scope | Number of studies | Findings | Key differences compared to current systematic review
Adabag, 2011^112^ | Effectiveness of CRT in patients with minimally symptomatic heart failure | 5 | Cardiac resynchronization therapy decreases all-cause mortality, reduces HF hospitalizations, and improves LVEF in NYHA functional class I/II HF patients. | Focused on minimally symptomatic patients (NYHA I–II). Included LVEF≤40%.
Bryant, 2013^113^ | CRT and QRS duration | 44 | The benefit of CRT appears restricted to those with a baseline QRS duration > 150ms | Focused on the effect of QRS duration and response to CRT. Included studies with QRS duration <120ms. Included studies enrolling patients with LVEF>35%
Ganesan, 2012^114^ | AV node ablation and CRT | 6 | AV nodal ablation was associated with a reduction in mortality and improvements in NYHA functional class compared with medical therapy. | Focused exclusively on patients with AF.
Garg, 2013^115^ | CRT and chronic kidney disease | 18 | CRT improves left ventricular and renal function in patients with CKD heart failure | Restricted to assessing the effect of CRT on kidney function. Did not restrict studies to an LVEF≤35% and QRS duration ≥120ms.
Hess, 2013^116^ | CRT and AF | 12 | The combined rate of conversion from persistent or permanent AF to sinus rhythm was 0.107 amongst CRT patients. | Focused on studies reporting the effect of CRT on AF Note: Only 1 reviewer assessed studies
Jiang, 2012^111^ | Comparison of CRT-D vs CRT-P | 7 | There is evidence of some superiority of CRT-D over CRT-P, combining randomized and non-randomized trials. | Included observational studies as well as RCTs in effectiveness analysis of CRT-D vs. CRT-P.
Lubitz, 2010^117^ | Effectiveness of CRT in patients with minimally symptomatic heart failure | 2 | CRT reduces heart failure events in patients with mild heart failure symptoms, left ventricular dysfunction, sinus rhythm, and a prolonged QRS duration. | Enrolled only NYHA Class I and II patients.
McAlister, 2004^118^ | Effectiveness and harms of CRT in patients with NYHA class III and IV. | 27 | CRT improves functional and hemodynamic status, reduces heart failure hospitalizations, and reduces all-cause mortality. | Older systematic review which thus did not include several large RCTs published subsequently (contained only patients with NYHA class III–IV symptoms) Included trials of LV only pacing. Did not examine remodeling outcomes (changes in LVEF, LVESV, or LVEDV)
McAlister, 2007^110^ | Effectiveness and harms of CRT | 195 | CRT reduces morbidity and mortality in patients with LV systolic dysfunction, prolonged QRS duration, and NYHA class III or IV when combined with optimal medical therapy. | Older systematic review which thus did not include several large RCTs published subsequently Included trials of LV only pacing. Did not look at changes in LVESV or LVEDV
Nery, 2011^119^ | Effect of CRT in patients with RBBB | 5 | There is no benefit of patients with RBBB although more data are needed. | Looked at RBBB population specifically.
Proietti, 2014^120^ | CRT and cognitive improvement | 3 | There were not enough data to assess CRT effect on cognitive function. | Focused on the effect of CRT on cognitive function. Did not restrict studies to an LVEF≤35% and QRS duration ≥120ms.
Santangeli, 2011^121^ | Effectiveness of CRT in patients with minimally symptomatic heart failure | 5 | Among patients with mild (NYHA II) heart failure, CRT reduces mortality and the risk of heart failure events, induces LV reverse remodeling and slows the progression of heart failure symptoms. | Focused on minimally symptomatic patients (NYHA I–II). Included LVEF≤40%.
Tu R, 2011^122^ | Effectiveness of CRT in patients with minimally symptomatic heart failure | 8 | CRT improves outcomes in patients with mild heart failure and ventricular dyssynchrony. The improvements are accompanied by more adverse events. | Focused on minimally symptomatic patients (NYHA I–II). Included LVEF≤40%.
Van Rees, 2011^123^ | Complications of CRT-D vs. an ICD alone | 18 | Lead dislodgement was higher for CRT-D vs. an ICD alone. Incidence of pneumothorax were similar between ICD vs. CRT. | Included randomized controlled trials only. Excluded crossover trials. Included trials with QRS<120 ms Included non-CRT trials. Focused exclusively on complications.
Wilton, 2011^124^ | Effect of CRT in patients with AF | 23 | The benefits of CRT appear to be attenuated in patients with AF. | Focused exclusively on atrial fibrillation population.

## Applicability

The generalizability of these results is slightly limited. Race was reported very infrequently, prohibiting an assessment of applicability based on racial differences. The majority of patients included in the RCTs were male, although a large focus in sub-studies has been given to the role of CRT in women, given the heightened response to therapy seen in this population. The average age in the RCTs and cohort studies was in the mid 60s although many patients included were in the age range of the elderly Medicare population. There has not been an RCT that specifically enrolled Medicare eligible patients. Also, data for very elderly patients (> 75 years of age) are limited. In cohort studies and subgroup analyses from the RCTs, age was not found to be an important predictor of outcomes. Taken together, the results of our review are fairly generalizable to the Medicare population although given the absence of dedicated RCTs, a definitive statement of generalizability to this population is not possible.

## Limitations of the Comparative Effectiveness Review Process

In addressing the questions of efficacy of CRT-D and CRT-P (KQs 1A, 3A, and 5), several studies potentially of interest were excluded since they were non-randomized. For the questions about the predictors of response to CRT (KQs 1b and 3b), many retrospective cohort studies were excluded because of a mixed population of patients who received CRT-D or CRT-P devices. We attempted to contact the authors of such studies to obtain the device-specific data. We contacted the authors of 24 studies, of which we received responses from 2 authors with sufficient information to include in our review. In addition, many cohorts, which contained outcomes of interest were excluded due to failure to control for gender and QRS duration and/or morphology, important baseline confounders. Finally, we did not include prior or conduct new individual patient data meta-analyses to assess predictors. Therefore, our analyses may suggest that clinically relevant subgroup effects exist, but we are unable to quantify the effects reliably or precisely.

## Limitations of the Evidence Base

Multiple well-conducted RCTs were identified addressing the questions about the efficacy or CRT-D and CRT-P (KQs 1a and 3a). The majority of patients enrolled in the clinical trials had NYHA class II–IV heart failure symptoms. The applicability of the current findings to class I patients is less clear. In contrast, for the comparison of CRT-D with CRT-P (KQ 5), only the COMPANION trial was found to include both CRT-D and CRT-P arms.4 However, a direct comparison of the CRT-D to CRT-P arms was not reported for several outcomes. For the questions examining predictors of response to CRT (KQs 1b and 3b), many of the included cohort studies were relatively small. While all studies controlled for gender and either QRS duration or morphology based on our pre-specified inclusion criteria, the remaining variables in the model varied widely between studies. Similarly, many studies used statistical criteria to create their multivariate adjustments, not including important a priori clinical factors.

## Research Gaps

There is convincing evidence that CRT-D results in reverse ventricular remodeling and improvements in quality of life compared to an ICD alone. However, only two trials showed a mortality benefit of CRT-D over ICD alone. One trial primarily contained patients with minimally symptomatic heart failure. A second study found a mortality advantage in minimally symptomatic patients with LBBB but not non-LBBB morphologies. This study did not report the mortality data in the non-subdivided population and had an issue with significant patient loss to follow up. Whether CRT-D results in improved survival compared to an ICD alone in patients with advanced heart failure is unclear.

Several subgroup analyses from the RCTs as well as cohort studies demonstrate superior outcomes in patients with a native LBBB compared to a non-LBBB. Subgroup analysis from the MADIT-CRT trial suggested possible harm for CRT-D versus an ICD alone in non-LBBB patients.6, 41 Subgroup analyses from other RCTs suggested little benefit of CRT in non-LBBB patients (but no convincing trend towards harm).7 One important issue with the assessment of CRT efficacy according to QRS morphology is the interaction between QRS duration, another variable with impact on outcome, and morphology. Patients with a LBBB tend to have wider QRS durations than patients with non-LBBBs. Several retrospective studies have attempted to determine the relative impact on outcomes of QRS duration within various QRS morphology groups in patients receiving a CRT device with mixed results.125, 126 There has not been an RCT which compares CRT to a control in patients with a non-LBBB morphology. Given the lack of such a trial, the ability to conclude definitively that CRT is ineffective or, in fact harmful, in patients with non-LBBB morphology is limited.

Similarly, subgroup analyses from RCTs suggest limited benefit of CRT in patients with atrial fibrillation. Outside the small MUSTIC-AF study, CRT trial data focused on the AF population are lacking.45 Therefore, the ability to definitively conclude a lack of benefit in patients with AF receiving CRT is not possible.

The effectiveness of CRT-D versus CRT-P in patients with an LVEF≤35% has not been adequately addressed. The COMPANION trial which included both arms, did not directly compare the CRT types and is therefore inadequate to answer this question definitively.4

In Tables 62 to 64, we use the PICOS (Population, Intervention, Comparison, Outcomes, and Study design) framework to outline characteristics of an ideal study.

Table 62 Characteristics of an ideal study to compare the effectiveness of CRT-D vs. CRT-P

PICOS | Characteristics
Population | - Patients with an LVEF≤35% despite optimal medical therapy; - Patients with a QRS duration ≥120%; - NYHA class:; □ Subgroup 1: NYHA I–II heart failure; □ Subgroup 2: NYHA III–IV heart failure
Intervention | - Cardiac resynchronization therapy with defibrillator
Comparisons | - Cardiac resynchronization therapy without defibrillator
Outcomes and timing | - All-cause mortality with followup at least 3 years; - Heart failure hospitalizations with followup at least 3 years; - Quality of life score (Minnesota Living with Heart Failure Questionnaire) at 6 months; - Harms: lead dislodgement, infection, cardiac perforation/tamponade with followup at least 3 years
Study design | - Randomized controlled trial

Table 63 Characteristics of an ideal study to compare the effectiveness of CRT-D in patients with a non-left bundle branch block morphology

PICOS | Characteristics
Population | - Patients with an LVEF≤35% despite optimal medical therapy; - Patients with a QRS duration ≥120%; - NYHA class:; □ Subgroup 1: NYHA I–II heart failure; □ Subgroup 2: NYHA III–IV heart failure; □ Subgroup 3: QRs duration >150 ms; □ Subgroup 4: QRS duration 120–150 ms; - Non-LBBB morphology on 12 lead ECG prior to CRT:; □ Right bundle branch block or non-specific intraventricular conduction delay
Intervention | - Cardiac resynchronization therapy with defibrillator
Comparisons | - ICD alone
Outcomes and timing | - All-cause mortality with followup at least 3 years; - Heart failure hospitalizations with followup at least 3 years; - Change in left ventricular ejection fraction at 6 months; - Change in left ventricular end-systolic volume (ml) at 6 months; - Change in 6 minute hall walk distance at 6 months; - Quality of life score (Minnesota Living with Heart Failure Questionnaire) at 6 months; - Harms: pneumothorax, inappropriate ICD shocks, lead dislodgement, infection, cardiac perforation/tamponade with followup at least 3 years
Study design | - Randomized controlled trial

Table 64 Characteristics of an ideal study to compare the effectiveness of CRT-D in patients with atrial fibrillation

PICOS | Characteristics
Population | - Patients with an LVEF≤35% despite optimal medical therapy; - Patients with a QRS duration ≥120%; - NYHA III–IV heart failure; - Arm 1: Paroxysmal or persistent atrial fibrillation with controlled rates either medically or with concomitant AV node ablation; - Arm 2 Permanent AF with controlled rates either medically or with concomitant AV node ablation
Intervention | - Cardiac resynchronization therapy with defibrillator
Comparisons | - ICD alone
Outcomes and timing | - All-cause survival with followup at least 3 years; - Heart failure hospitalizations with followup at least 3 years; - Change in LVEF at 6 months; - Change in LVESV at 6 months; - Change in 6 minute hall walk distance at 6 months; - Quality of life score (Minnesota Living with Heart Failure Questionnaire) at 6 months; - Harms: pneumothorax, inappropriate ICD shocks, lead dislodgement, infection, cardiac perforation/tamponade with followup at least 3 years
Study design | - Randomized controlled trial

## Conclusion

We performed a systematic review to evaluate the efficacy and safety of CRT-D and CRT-P devices as well as predictors of outcomes following implant of such devices. There is convincing evidence that CRT-D is effective with regard to improvements in multiple outcomes compared to an ICD alone in patients with an LVEF≤35% and a QRS duration ≥120ms. These findings are based on patients primarily with NYHA class II–IV heart failure. The applicability of these findings to patients with NYHA class I symptoms is unclear. Similarly, there is convincing evidence that CRT-P is effective in improving multiple endpoints compared to optimal medical therapy alone in the same population. These data are primarily derived from NYHA class III–IV and the applicability to patients with NYHA class I and II is less clear. Female gender, LBBB, a widened QRS duration, sinus rhythm, and non-ischemic cardiomyopathy are associated with improved outcomes following CRT.