# List of Ongoing and Completed Studies in CRT Sponsored by Medtronic

Table E1 Ongoing Studies

Ongoing Study Title | NCT # | Study Status | Results: | JHU Database (Included, Exclude, Not Captured)
4195 Chronic Performance Study | NCT00869921 | Recruiting | No Results Available | NA
4195 Chronic Performance Study | NCT00869921 | Recruiting | No Results Available | NA
4196 Chronic Performance Study | NCT00930904 | Recruiting | No Results Available | NA
4296 Chronic Performance Study | NCT01361672 | Recruiting | No Results Available | NA
4396 Chronic Performance Study | NCT01361685 | Recruiting | No Results Available | NA
AdaptResponse Clinical Trial | NCT02205359 | Recruiting | No Results Available | NA
Assessment of Efficacies of Cardiac Resynchronization Therapies (CRT-P/D) for Heart Failure Patients in China | NCT01018667 | Recruiting | No Results Available | NA
Attain Performa(TM) Quadripolar Lead Study | NCT01751022 | Active, not recruiting | Abstract submitted to AHA 2014, not yet published, appended | NA
CARE-HF LTFU: CArdiac REsynchronization in Heart Failure Long-Term Follow-up | NCT00318357 | Active, not recruiting | Cleland JGF, Freemantle, N, Erdmann, E (2012). Long-term mortality with cardiac resynchronization therapy in the Cardiac Resynchronization-Heart Failure (CARE-HF) trial. European Journal of Heart Failure, 14, 628–634. doi:10.1093/eurjhf/hfs055 | Yes-Included
Improve Sudden Cardiac Arrest Study | NCT02099721 | Recruiting | No Results Available | NA
Integrated Diagnostic for Heart Failure | NCT01798797 | Recruiting | No Results Available | NA
Italian ClinicalService Project | NCT01007474 | Recruiting | 1. Santini, M, Gasparini, M, Landolina, M, (2011). Device-Detected Atrial Tachyarrhythmias Predict Adverse Outcome in Real-World Patients With Implantable Biventricular Defibrillators. Journal of the American College of Cardiology, 57(2), 167–72. doi:10.1016/j.jacc.2010.08.624; 2. Landolina, M, Gasparini, M, Lunati, M et al. (2011). Long-Term Complications Related to Biventricular Defibrillator Implantation: Rate of Surical Revisions and Impact on Survival: Insights From the Italian ClinicalService Database. Circulation. 123, 2526-2535. DOI: 10.1161/CIRCULATIONAHA.110.015024; 3. Ricci RP, Pignalberi C, Landolina M, et al. (2014). Ventricular rate monitoring as a tool to predict and prevent atrial fibrillation-related inappropriate shocks in heart failure patients treated with cardiac resynchronisation therapy defibrillators. Heart; 100:848–854. doi:10.1136 | 1. Yes-Excluded (This study did not address any of our Key Questions); 2. Yes-Included; 3. will be included in the final report
Latin America Cardiac Resynchronization Therapy Study | NCT01238874 | Enrolling by invitation | No Results Available | NA
Medtronic South Asian Systolic Heart Failure Registry | NCT01434615 | Active, not recruiting | No Results Available | NA
MOnitoring REsynchronization deviCes and cARdiac patiEnts | NCT00885677 | Recruiting | Boriani, G, Antoine Da Costa, A, Ricci, RP, (2013) The MOnitoring Resynchronization dEvices and CARdiac patiEnts (MORECARE) Randomized Controlled Trial: Phase 1 Results on Dynamics of Early Intervention With Remote Monitoring. J Med Internet Res, 15(8): e167. doi:10.2196/jmir.2608 | Yes-Excluded (Did not address any of our Key Questions)
OptiLink HF Study: Optimization of Heart Failure Management Using Medtronic OptiVol Fluid Status Monitoring and CareLink Network | NCT00769457 | Recruiting | No Results Available | NA
PANORAMA 2 Observational Study | NCT01723566 | Recruiting | No Results Available | NA
Post-Myocardial Infarction Remodeling Prevention Therapy | NCT01213251 | Active, not recruiting | No Results Available | NA
The Product Surveillance Registry REVERSE Post Approval Study | NCT01660035 | Recruiting | No Results Available | NA

NA-Not applicable, ICD- Implantable Cardiac Defibrillator, KQ- Key question, CRT- Cardiac resynchronization, CRT-D- Cardiac resynchronization defibrillator, CRT-P- Cardiac resynchronization pacemaker

Table E2 Completed Studies

Completed/Terminated Study Title | NCT # | Study Status | Results: | Status
4196 Attain Ability IDE | NCT00271544 | Completed | NCT Posted | NA
4296 Attain Ability Plus | NCT00927251 | Completed | NCT Posted | NA
4396 Attain Ability Straight IDE | NCT00853593 | Completed | NCT Posted | NA
Adaptive Cardiac Resynchronization Therapy Study | NCT00980057 | Completed | 1. Martin DO, Lemke B, Birnie D, et al. (2012). Investigation of a novel algorithm for synchronized left-ventricular pacing and ambulatory optimization of cardiac resynchronization therapy: results of the adaptive CRT trial. Heart Rhythm. 9(11):1807-14. doi: 10.1016/j.hrthm.2012.07.009.; 2. AF Results abstract appended; 3. 30-day readmission abstract appended | 1. Yes-Excluded (Did not address any of our Key Questions); 2. NA; 3. NA
ADVANCE CRT - D: Antitachycardia Pacing (ATP) Delivery for Painless Implantable Cardioverter Defibrillator (ICD) Therapy | NCT00147290 | Completed | NCT posted | NA
Avoid DeliVering TherApies for Non-sustained Arrhythmias in ICD PatiEnts III (ADVANCEIII) | NCT0061717 | Completed | 1. NCT Posted; 2. Maurizio Gasparini, M, Proclemer, A, Klersy, C et al. (2013). Effect of Long-Detection Interval vs Standard-Detection Interval for Implantable Cardioverter-Defibrillators on Antitachycardia Pacing and Shock Delivery The ADVANCE III Randomized Clinical Trial. JAMA, 309(18):1903-1911.; 3. Proclemer, A, Arenal, A, Lunati, M et al. (2014). Association of Long vs Standard Detection Intervals for Implantable Cardioverter-Defibrillators With Hospitalizations and Costs. JAMA, 312(5):555-557. | 1. NA; 2. Not Captured (Reviews ICD only); 3. Not Captured (Reviews ICD only)
APAF: Assessment of Cardiac Resynchronization Therapy in Patients With Permanent Atrial Fibrillation | NCT00111527 | Completed | Brignole M, Botto G, Mont L, et al. (2011). Cardiac resynchronization therapy in patients undergoing atrioventricular junction ablation for permanent atrial fibrillation: a randomized trial. Eur Heart J. 32(19):2420-9. doi: 10.1093/eurheartj/ehr162. | Yes-Included
Attain™ Bipolar OTW Model 4194 US Clinical Study | Not Registered | Completed | Johnson, WB, Hoyt, R, Bailin, S, et al. (2005). Relationship between LV pacing thresholds, R-wave amplitudes, and impedances to LV vein size and locations in a bipolar LV lead. Heart Rhythm;2(5): S123–S124, doi:http://dx.doi.org/10.1016/j.hrthm.2005.02.385 | Not Captured (Addresses technical aspects not our KQ)
Attain StarFix IDE | NCT00269230 | Completed | Crossley, GH, Exner, D, Mead, RH, Sorrentino, RA, et al. (2010). Chronic performance of an active fixation coronary sinus lead. Heart Rhythm; 7(4), doi:10.1016/j.hrthm.2010.01.007 | Yes-Excluded (Not relevant to our Key Questions)
Attain Success | NCT00990964 | Completed | NCT Posted | NA
Biventricular Versus Right Ventricular Pacing in Heart Failure Patients With Atrioventricular Block (BLOCK HF) | NCT00267098 | Completed | 1. NCT posted; 2. Curtis, AB, Worley, SJ, Adamson, PB, et al. (2013). Biventricular Pacing for Atrioventricular Block and Systolic Dysfunction. N Engl J Med; 368:1585-93. DOI: 10.1056/NEJMoa1210356 | 1. NA; 2. Yes-Included
Care-HF CArdiac Resynchronization in Heart Failure | NCT00170300 | Completed | 1. Cleland, JGF, Daubert, JC, Erdmann, E, et al. (2005). The Effect of Cardiac Resynchronization on Morbidity and Mortality in Heart Failure. N Engl J Med;352:1539–49.; 2. Wikstrom, G, Lundqvist, CB, Andren, B, et al. (2009). The effects of aetiology on outcome in patients treated with cardiac resynchronization therapy in the CARE-HF trial. European Heart Journal; 30, 782–788, doi:10.1093/eurheartj/ehn577; 3. Yao, G, Freemantle, N, Calvert, MJ, et al. (2007). The long-term cost-effectiveness of cardiac resynchronization therapy with or without an implantable cardioverter-defibrillator. European Heart Journal 28, 42–51, doi:10.1093/eurheartj/ehl382 | 1. Yes-Included; 2. Yes-Included; 3. Yes-Excluded (Not relevant to our Key Questions)
CARIBE HF | Not Registered | Completed | Grosu, A, Senni, M, Iacovoni, A, (2011). CArdiac resynchronization in combination with beta blocker treatment in advanced chronic heart failure (CARIBE-HF): the results of the CARIBE-HF study. Acta Cardiol;66(5):573-80 | Yes-Excluded (Not relevant to our Key Questions)
Clinical Investigation of the Medtronic Concerto™ Device | NCT00268320 | Completed | Crossley GH, Aonuma K, Haffajee C, et al. (2009). Atrial fibrillation therapy in patients with a CRT defibrillator with wireless telemetry. Pacing Clin Electrophysiol. 32(1):13–23. doi: 10.1111/j.1540-8159.2009.02171.x | Yes-Excluded (Not relevant to our Key Questions)
Compare Remote Patient Management and Standard Care in CRT-D and ICD-patients to Assess the Effect on Heart Failure | NCT00730548 | Completed | Zabel M, Vollmann D, Lüthje L, et al (2013). Randomized Clinical evaluatiON of wireless fluid monitoriNg and rEmote ICD managemenT using OptiVol alert-based predefined management to reduce cardiac decompensation and health care utilization: the CONNECT-OptiVol study. Contemp Clin Trials; 34(1):109–16. doi: 10.1016/j.cct.2012.10.001. | #944- Yes-Excluded (Not relevant to our Key Questions)
CONNECT Study - Clinical Evaluation Of Remote NotificatioN to rEduCe Time to Clinical Decision | NCT00402246 | Completed | 1. NCT Posted; 2. Crossley, GH, Boyle, A, Vitense, H, et al. (2011) The CONNECT (Clinical Evaluation of Remote Notification to Reduce Time to Clinical Decision) Trial: The Value of Wireless Remote Monitoring With Automatic Clinician Alerts. J. Am. Coll. Cardiol. 2011;57;1181-1189, doi:10.1016/j.jacc.2010.12.012 | 1. NA; 2. Not Captured (Not relevant to key questions)
Diagnostic Outcome Trial in Heart Failure (DOT-HF Trial) | NCT00480077 | Terminated | van Veldhuisen DJ, Braunschweig F, Conraads V, et al. (2011). Intrathoracic impedance monitoring, audible patient alerts, and outcome in patients with heart failure. Circulation; 18;124(16):1719-26, doi:10.1161/CIRCULATIONAHA.111.043042. | Not Captured (Not randomized and does not address relevant Key Questions)
EVOLVO | NCT00873899 | Completed | Landolina M, Perego GB, Lunati M, et al. (2012). Remote monitoring reduces healthcare use and improves quality of care in heart failure patients with implantable defibrillators: the evolution of management strategies of heart failure patients with implantable defibrillators (EVOLVO) study. Circulation; 125(24):2985-92. doi: 10.1161/CIRCULATIONAHA.111.088971. | Yes-Excluded (Does not evaluate a CRT)
FAST | NCT0028927 | Completed | Abraham, WT, Compton, S, Haas, G et al. (2011). Intrathoracic Impedance vs Daily Weight Monitoring for Predicting Worsening Heart Failure Events: Results of the Fluid Accumulation Status Trial (FAST). Congest Heart Fail; 17(2):51–5, doi: 10.1111/j.1751-7133.2011.00220.x | Yes-Excluded (Not relevant to our Key Questions)
IMPROVE-HF | NCT00303979 | Completed | 1. Curtis, AB, Yancy, CW, Albert, NM, et al. (2009). Cardiac resynchronization therapy utilization for heart failure: Findings from IMPROVE HF. Congestive Heart Failure; 158(6):956-964, doi:10.1016/j.ahj.2009.10.011.; 2. Fonarow, GC, Albert, NM, Anne B. Curtis, AB, et al. (2010). Improving Evidence-Based Care for Heart Failure in Outpatient Cardiology Practices Primary Results of the Registry to Improve the Use of Evidence-Based Heart Failure Therapies in the Outpatient Setting (IMPROVE HF). Circulation; 22:585-596, DOI:10.1161/CIRCULATIONAHA.109.934471; 3. Shukla, A, Curtis, AB, Mehra, MR et al. (2013). Factors Associated with Improvement in Utilization of Cardiac Resynchronization Therapy in Eligible Heart Failure Patients: Findings from IMPROVE HF. PACE; 36: 433-443, doi: 10.1111/pace.12090; 4. Fonarow, GC, Albert, NM, Curtis, AB et al. (2011). Associations Between Outpatient Heart Failure Process-of-Care Measures and Mortality. Circulation; 123;1601-1610, DOI: 10.1161/CIRCULATIONAHA.110.989632 | 1. Yes-Excluded (Not relevant to our Key Questions); 2. Yes-Excluded (Not relevant to our Key Questions); 3. Yes-Excluded (Not relevant to our Key Questions); 4. Yes-Excluded (Not relevant to our Key Questions)
InSync III | Not Registered | Completed | León, AR, Abraham, WT, Brozena, S et al. (2005). Cardiac Resynchronization With Sequential Biventricular Pacing for the Treatment of Moderate-to-Severe Heart Failure. Journal of the American College of Cardiology; 46(12):2298–304, doi:10.1016/j.jacc.2005.08.032 | Yes-Included
InSync III Marquis | NCT00271232 | Completed | Abraham, WT, León, AR, St. John Sutton, MG, et al. (2012). Randomized controlled trial comparing simultaneous versus optimized sequential interventricular stimulation during cardiac resynchronization therapy. Am Heart J; 164:735-41. | Yes-Excluded (Not relevant to our Key Questions)
InSync Model 8040 (InSync) and InSync III Model 8042 (InSync III) Registry | NCT00273182 | Completed | NCT posted | NA
InSync Sentry Registry | Not Registered | Completed | Vollmann, D, Nägele, H, Schauerte, P, et al. (2007). Clinical utility of intrathoracic impedance monitoring to alert patients with an implanted device of deteriorating chronic heart failure. Eur Heart J; 28 (15): 1835–1840, doi: 10.1093/eurheartj/ehl506 | Yes-Excluded (Does not evaluate a CRT)
InSync Study | Not Registered | Completed | Gras, D, Leclercq, C, Tang, ASL, et al. (2002). Cardiac resynchronization therapy in advanced heart failure the multicenter InSync clinical study. The European Journal of Heart Failure; 4:311–320. | Yes-Included
Left Ventricular Capture Management Study | NCT01089634 | Completed | Crossley, GH, Mead, H, Kleckner, K, et al. (2007). Automated Left Ventricular Capture Management. PACE; 30:1190–1200. | Not Captured (Not relevant to our Key Questions)
Medtronic Shock-Less Study on Physician Utilization of Shock Reduction Programming | NCT00856349 | Completed | NCT posted | NA
MIRACLE | Not Registered | Completed | 1. Abraham, WT, Fisher, WG, Smith AL, et al. (2002). Cardiac Resynchronization in Chronic Heart Failure. N Engl J Med; 346(24):1845–1853.; 2. León, AR, Abraham, WT, Curtis, AB, et al. (2005). Safety of Transvenous Cardiac Resynchronization System Implantation in Patients With Chronic Heart Failure Combined Results of Over 2,000 Patients From a Multicenter Study Program. Journal of the American College of Cardiology. 46(12):2348–56, doi:10.1016/j.jacc.2005.08.031. | 1. Yes-Included; 2. Yes-Included
MIRACLE ICD | Not Registered | Completed | Young, JB, Abraham, WT, Smith, AL et al. (2003). Combined Cardiac Resynchronization and Implantable Cardioversion Defibrillation in Advanced Chronic Heart Failure: The MIRACLE ICD Trial. JAMA; 289(20):2685–2694, doi:10.1001/jama.289.20.2685. | Yes-Included
MIRACLE ICD II | Not Registered | Completed | Abraham, WT, Young, JB, León, AR, et al. (2004). Effects of Cardiac Resynchronization on Disease Progression in Patients With Left Ventricular Systolic Dysfunction, an Indication for an Implantable Cardioverter-Defibrillator, and Mildly Symptomatic Chronic Heart Failure. Circulation; 110:2864–2868, doi:10.1161/01.cir.0000146336.92331.d1. | Yes-Included
MOMIJI | Not Registered | Completed | Momomura, S, Tsutsui, H, Sugawara, Y, et al. (2012). Clinical Efficacy of Cardiac Resynchronization Therapy With an Implantable Defibrillator in a Japanese Population – Results of the MIRACLE-ICD Outcome Measured in Japanese Indication (MOMIJI) Study –. Circulation Journal; doi: 10.1253/circj.CJ-11-1341. | Yes-Excluded (Not relevant to our Key Questions)
OMNI | NCT00277524 | Completed | Sweeney, MO, Sakaguchi, S, Simons, G, et al. (2012). Response to the Center for Medicare & Medicaid Services coverage with evidence development request for primary prevention implantable cardioverter-defibrillators: Data from the OMNI study. Heart Rhythm; 9(7):1058–1066, doi:10.1016/j.hrthm.2012.02.027. | Yes-Excluded (Not relevant to our Key Questions)
OptiVol® Care Pathway | NCT00847288 | Completed | NCT posted | NA
PANORAMA | NCT00382525 | Completed | Al Kandari F, et al, Regional variations in baseline characteristics of cardiac rhythm device recipients: The PANORAMA observational cohort study, IJC Heart & Vessels (2014), http://dx.doi.org/10.1016/j.ijchv.2014.06.008 | Not Captured (Not relevant to our key questions)
PARTNERS HF: Program to Access and Review Trending Information and Evaluate Correlation to Symptoms in Patients With Heart Failure | NCT00279955 | Completed | NCT posted | NA
Primary Prevention Parameters Evaluation Study (PREPARE) | NCT00279279 | Completed | Wilkoff, B. L., Williamson, B. D., Stern, R. S., et al. (2008). Strategic programming of detection and therapy parameters in implantable cardioverter-defibrillators reduces shocks in primary prevention patients: results from the PREPARE (Primary Prevention Parameters Evaluation) study. J Am Coll Cardiol, 52(7), 541–550. doi: 10.1016/j.jacc.2008.05.011 | Not Captured (Not relevant to our key questions)
Progressive Ventricular Dysfunction Prevention in Pacemaker Patients | NCT00170326 | Completed | Stockburger M1, Gómez-Doblas JJ, Lamas G, et al. (2011). Preventing ventricular dysfunction in pacemaker patients without advanced heart failure: results from a multicentre international randomized trial (PREVENT-HF). Eur J Heart Fail;13(6):633–41. doi: 10.1093/eurjhf/hfr041. | Yes-Included
Prospect | NCT00253357 | Completed | 1. Chung, E. S., Leon, A. R., Tavazzi, L., et al. (2008). Results of the Predictors of Response to CRT (PROSPECT) trial. Circulation, 117(20), 2608–2616. doi: 10.1161/CIRCULATIONAHA.107.743120; 2. Sullivan RM, Murillo J, Gerritse B, et al. (2013). Do baseline diastolic echocardiographic parameters predict outcome after resynchronization therapy? Results from the PROSPECT trial. Pacing Clin Electrophysiol. 36(2):214–20. doi: 10.1111/pace.12042. | 1. Yes-Excluded; 2. Yes-Excluded
REsynchronization reVErses Remodeling in Systolic Left vEntricular Dysfunction (REVERSE) | NCT00271154 | Completed | 1. Gold, M. R., Daubert, J. C., Abraham, W. T., et al. (2013). Implantable defibrillators improve survival in patients with mildly symptomatic heart failure receiving cardiac resynchronization therapy: analysis of the long-term follow-up of remodeling in systolic left ventricular dysfunction (REVERSE). Circ Arrhythm Electrophysiol, 6(6), 1163-1168. doi: 10.1161/CIRCEP.113.000570; 2. Linde, C., Abraham, W. T., Gold, M. R., et al. (2008). Randomized trial of cardiac resynchronization in mildly symptomatic heart failure patients and in asymptomatic patients with left ventricular dysfunction and previous heart failure symptoms. J Am Coll Cardiol, 52(23), 1834-1843. doi: 10.1016/j.jacc.2008.08.027; 3. Linde, C., Gold, M. R., Abraham, et al. (2013). Long-term impact of cardiac resynchronization therapy in mild heart failure: 5-year results from the REsynchronization reVErses Remodeling in Systolic left vEntricular dysfunction (REVERSE) study. Eur Heart J, 34(33), 2592-2599. doi: 10.1093/eurheartj/eht160; 4. Linde, C., Mealing, S., Hawkins, N., et al. (2011). Cost-effectiveness of cardiac resynchronization therapy in patients with asymptomatic to mild heart failure: insights from the European cohort of the REVERSE (Resynchronization Reverses remodeling in Systolic Left Ventricular Dysfunction). Eur Heart J, 32(13), 1631-1639. doi: 10.1093/eurheartj/ehq408 | 1. Yes-Excluded (Population inclusion criteria do not fall within the QRS>/=120ms range and LVEF</=35%); 2. Yes-Excluded (Population inclusion criteria do not fall within the QRS>/=120ms range and LVEF</=35%); 3. Yes-Excluded (Population inclusion criteria do not fall within the QRS>/=120ms range and LVEF</=35%); 4. Yes-Excluded (Not relevant to key questions)
Resynchronization/Defibrillation for Ambulatory Heart Failure Trial (RAFT) | NCT00251251 | Completed | Tang, ASL, Wells, GA, Talajic, M et al. (2010). Cardiac-Resynchronization Therapy for Mild-to-Moderate Heart Failure. N Engl J Med; doi: 10.1056/NEJMoa1009540 | Yes-Included
Role of long dEtection window programming in patients with LEft VentriculAr dysfunction, Non-ischemic eTiology in primary prevention treated with a biventricular ICD study (RELEVANT) | Not Registered | Completed | Gasparini, M., Menozzi, C., Proclemer, A, et al. (2009). A simplified biventricular defibrillator with fixed long detection intervals reduces implantable cardioverter defibrillator (ICD) interventions and heart failure hospitalizations in patients with non-ischaemic cardiomyopathy implanted for primary prevention: the RELEVANT [Role of long dEtection window programming in patients with LEft VentriculAr dysfunction, Non-ischemic eTiology in primary prevention treated with a biventricular ICD] study. Eur Heart J, 30(22), 2758-2767. doi: 10.1093/eurheartj/ehp247 | Yes-Included
Sense HF | NCT00400985 | Completed | Conraads, V. M., Tavazzi, L., Santini, M., et al. (2011). Sensitivity and positive predictive value of implantable intrathoracic impedance monitoring as a predictor of heart failure hospitalizations: the SENSE-HF trial. Eur Heart J, 32(18), 2266-2273. doi: 10.1093/eurheartj/ehr050 | Yes-Excluded (Does not evaluate a CRT)
Study to Characterize Atrial Fibrillation in CHF Patients Indicated for CRT | NCT00156728 | Completed | Leclercq, C, Pedeletti, L, Ritter, P, et al. (2006). Unexpectedly Low Incidence of Atrial Fibrillation in Heart Failure Patients Treated by Cardiac Resynchronization Therapy Circulation;114(II)_617. | NR (Does not address Key Questions)
Study to Evaluate System Safety and Clinical Performance of the Protecta Implantable Cardioverter Defibrillator (ICD) Plus Cardiac Resynchronization Therapy Defibrillator (CRT-D) | NCT00982397 | Completed | Wollmann, C. G., Lawo, T., Kuhlkamp, V., et al. (2014). Implantable Defibrillators With Enhanced Detection Algorithms: Detection Performance and Safety Results from the PainFree SST Study. Pacing Clin Electrophysiol. doi: 10.1111/pace.12390 | Will be included in the final report

NA-Not applicable, ICD- Implantable Cardiac Defibrillator, KQ- Key question, CRT- Cardiac resynchronization, CRT-D- Cardiac resynchronization defibrillator, CRT-P- Cardiac resynchronization pacemaker

Other Results of Interest

Project Name | Results:
CRT Meta-Analysis Project | Cleland JG, Abraham WT, Linde C, et al. (2013). An individual patient meta-analysis of five randomized trials assessing the effects of cardiac resynchronization therapy on morbidity and mortality in patients with symptomatic heart failure. Eur Heart J;34(46):3547-56. doi: 10.1093/eurheartj/eht290. | Yes-Excluded (No original data (systematic reviews, meta-analysis, editorial, commentary)
United Kingdom National Institute for Health and Care Excellence (NICE) technology appraisal | National Institute for Health and Care Excellence. (2014). Implantable cardioverter defibrillators and cardiac resynchronisation therapy for arrhythmias and heart failure (review of TA95 and TA120). NICE technology appraisal guidance 314. guidance.nice.org.uk/ta314 Document package available at (manufacturer submission is document #13): http://www.nice.org.uk/guidance/ta314/resources/arrythmias-icds-heart-failure-cardiac-resynchronisation-evaluation-report4 | NR (Not relevant to key questions)

NA-Not applicable, ICD- Implantable Cardiac Defibrillator, KQ- Key question, CRT- Cardiac resynchronization, CRT-D- Cardiac resynchronization defibrillator, CRT-P- Cardiac resynchronization pacemaker