# Evidence tables

Table D1 Study characteristics of included articles

Table D2 Population characteristics –CRT P effectiveness

Table D3 Population characteristics –CRT P harms

Table D4 Population characteristics –CRT D effectiveness

Table D5 Population characteristics –CRT D harms

Table D6 Population characteristics –CRT P vs. D effectiveness

Table D7 Population characteristics –CRT P vs. D harms

Table D8 Population characteristics –CRT P clinical predictors

Table D9 Population characteristics –CRT D clinical predictors

Table D10 Outcomes reported in the trials assessing effectiveness of CRT P

Table D11 Outcomes reported in the trials assessing effectiveness of CRT-P (Hospitalization for heart failure and All-cause mortality)

Table D12 Harms reported in the studies assessing harms of CRT P

Table D13 Outcomes reported in the trials assessing effectiveness of CRT-D

Table D14 Outcomes reported in the trials assessing effectiveness of CRT-D (Hospitalization for heart failure and All-cause mortality)

Table D15 Harms reported in the studies assessing effectiveness of CRT-D

Table D16 Outcomes reported in the trials assessing effectiveness of CRT P vs. D

Table D17 Outcomes reported in the trials assessing effectiveness of CRT P vs. D (Hospitalization for heart failure and All-cause mortality)

Table D18 Harms reported in the studies assessing harms of CRT P vs. D

Table D19 Clinical predictors reported in the studies assessing response of CRT P

Table D20 Clinical predictors reported in the studies assessing response of CRT D

## Reference List

1 Cleland JG, Daubert JC, Erdmann E, et al. The effect of cardiac resynchronization on morbidity and mortality in heart failure. N Engl J Med. 2005;352(15):1539-1549. [pmid: 15753115].
2 Cleland JG, Daubert JC, Erdmann E, et al. Longer-term effects of cardiac resynchronization therapy on mortality in heart failure. Eur Heart J. 2006;27(16):1928-1932. [pmid: 16782715].
3 Cleland JG, Freemantle N, Daubert JC, Toff WD, Leisch F, Tavazzi L. Long-term effect of cardiac resynchronisation in patients reporting mild symptoms of heart failure: a report from the CARE-HF study. Heart. 2008;94(3):278-283. [pmid: 17984215].
4 Cleland JG, Calvert MJ, Verboven Y, Freemantle N. Effects of cardiac resynchronization therapy on long-term quality of life: an analysis from the CArdiac Resynchronisation-Heart Failure (CARE-HF) study. Am Heart J. 2009;157(3):457-466. [pmid: 19249415].
5 Cleland JG, Freemantle N, Erdmann E, et al. Long-term mortality with cardiac resynchronization therapy in the Cardiac Resynchronization-Heart Failure (CARE-HF) trial. Eur J Heart Fail. 2012;14(6):628-634. [pmid: 22552183].
6 Ghio S, Freemantle N, Scelsi L, et al. Long-term left ventricular reverse remodelling with cardiac resynchronization therapy: results from the CARE-HF trial. Eur J Heart Fail. 2009;11(5):480-488. [pmid: 19287017].
7 Gras D, Bocker D, Lunati M, et al. Implantation of cardiac resynchronization therapy systems in the CARE-HF trial: procedural success rate and safety. Europace. 2007;9(7):516-522. [pmid: 17540662].
8 Wikstrom G, Blomstrom-Lundqvist C, Andren B, et al. The effects of aetiology on outcome in patients treated with cardiac resynchronization therapy in the CARE-HF trial. Eur Heart J. 2009;30(7):782-788. [pmid: 19168870].
9 Moss AJ, Hall WJ, Cannom DS, et al. Cardiac-resynchronization therapy for the prevention of heart-failure events. N Engl J Med. 2009;361(14):1329-1338. [pmid: 19723701].
10 Arshad A, Moss AJ, Foster E, et al. Cardiac resynchronization therapy is more effective in women than in men: the MADIT-CRT (Multicenter Automatic Defibrillator Implantation Trial with Cardiac Resynchronization Therapy) trial. J Am Coll Cardiol. 2011;57(7):813-820. [pmid: 21310317].
11 Barsheshet A, Goldenberg I, Moss AJ, et al. Response to preventive cardiac resynchronization therapy in patients with ischaemic and nonischaemic cardiomyopathy in MADIT-CRT. Eur Heart J. 2011;32(13):1622-1630. [pmid: 21075774].
12 Goldenberg I, Moss AJ, Hall WJ, et al. Predictors of response to cardiac resynchronization therapy in the Multicenter Automatic Defibrillator Implantation Trial with Cardiac Resynchronization Therapy (MADIT-CRT). Circulation. 2011;124(14):1527-1536. [pmid: 21900084].
13 Goldenberg I, Kutyifa V, Klein HU, et al. Survival with cardiac-resynchronization therapy in mild heart failure. N Engl J Med. 2014;370(18):1694-1701. [pmid: 24678999].
14 Hsu JC, Solomon SD, Bourgoun M, et al. Predictors of super-response to cardiac resynchronization therapy and associated improvement in clinical outcome: the MADIT-CRT (multicenter automatic defibrillator implantation trial with cardiac resynchronization therapy) study. J Am Coll Cardiol. 2012;59(25):2366-2373. [pmid: 22698490].
15 Jamerson D, McNitt S, Polonsky S, Zareba W, Moss A, Tompkins C. Early Procedure-Related Adverse Events by Gender in MADIT-CRT. J Cardiovasc Electrophysiol. 2014;25(9):985-989. [pmid: 24758374].
16 Ouellet G, Huang DT, Moss AJ, et al. Effect of cardiac resynchronization therapy on the risk of first and recurrent ventricular tachyarrhythmic events in MADIT-CRT. J Am Coll Cardiol. 2012;60(18):1809-1816. [pmid: 23040580].
17 Penn J, Goldenberg I, Moss AJ, et al. Improved outcome with preventive cardiac resynchronization therapy in the elderly: a MADIT-CRT substudy. J Cardiovasc Electrophysiol. 2011;22(8):892-897. [pmid: 21831163].
18 Ruwald MH, Solomon SD, Foster E, et al. Left Ventricular Ejection Fraction Normalization in Cardiac Resynchronization Therapy and Risk of Ventricular Arrhythmias and Clinical Outcomes: Results from the MADIT-CRT Trial. Circulation. 2014. [pmid: 25301831].
19 Solomon SD, Foster E, Bourgoun M, et al. Effect of cardiac resynchronization therapy on reverse remodeling and relation to outcome: multicenter automatic defibrillator implantation trial: cardiac resynchronization therapy. Circulation. 2010;122(10):985-992. [pmid: 20733097].
20 Tompkins C, Kutyifa V, McNitt S, et al. Effect on cardiac function of cardiac resynchronization therapy in patients with right bundle branch block (from the Multicenter Automatic Defibrillator Implantation Trial With Cardiac Resynchronization Therapy. Am J Cardiol. 2013;112(4):525-529. [pmid: 23725995].
21 Zareba W, Klein H, Cygankiewicz I, et al. Effectiveness of Cardiac Resynchronization Therapy by QRS Morphology in the Multicenter Automatic Defibrillator Implantation Trial-Cardiac Resynchronization Therapy (MADIT-CRT). Circulation. 2011;123(10):1061-10672. [pmid: 21357819].
22 Tang AS, Wells GA, Talajic M, et al. Cardiac-resynchronization therapy for mild-to-moderate heart failure. N Engl J Med. 2010;363(25):2385-2395. [pmid: 21073365].
23 Birnie DH, Ha A, Higginson L, et al. Impact of QRS morphology and duration on outcomes after cardiac resynchronization therapy: Results from the Resynchronization-Defibrillation for Ambulatory Heart Failure Trial (RAFT). Circ Heart Fail. 2013;6(6):1190-1198. [pmid: 23995437].
24 Gillis AM, Kerr CR, Philippon F, et al. Impact of Cardiac Resynchronization Therapy on Hospitalizations in the Resynchronization-Defibrillation for Ambulatory Heart Failure Trial. Circulation. 2014. [pmid: 24610807].
25 Healey JS, Hohnloser SH, Exner DV, et al. Cardiac resynchronization therapy in patients with permanent atrial fibrillation: results from the Resynchronization for Ambulatory Heart Failure Trial (RAFT). Circ Heart Fail. 2012;5(5):566-570. [pmid: 22896584].
26 Young JB, Abraham WT, Smith AL, et al. Combined cardiac resynchronization and implantable cardioversion defibrillation in advanced chronic heart failure: the MIRACLE ICD Trial. JAMA. 2003;289(20):2685-2694. [pmid: 12771115].
27 Abraham WT, Fisher WG, Smith AL, et al. Cardiac resynchronization in chronic heart failure. N Engl J Med. 2002;346(24):1845-1853. [pmid: 12063368].
28 St John Sutton MG, Plappert T, Abraham WT, et al. Effect of cardiac resynchronization therapy on left ventricular size and function in chronic heart failure. Circulation. 2003;107(15):1985-1990. [pmid: 12668512].
29 Bristow MR, Saxon LA, Boehmer J, et al. Cardiac-resynchronization therapy with or without an implantable defibrillator in advanced chronic heart failure. N Engl J Med. 2004;350(21):2140-2150. [pmid: 15152059].
30 Anand IS, Carson P, Galle E, et al. Cardiac resynchronization therapy reduces the risk of hospitalizations in patients with advanced heart failure: results from the Comparison of Medical Therapy, Pacing and Defibrillation in Heart Failure (COMPANION) trial. Circulation. 2009;119(7):969-977. [pmid: 19204305].
31 Carson P, Anand I, O'Connor C, et al. Mode of death in advanced heart failure: the Comparison of Medical, Pacing, and Defibrillation Therapies in Heart Failure (COMPANION) trial. J Am Coll Cardiol. 2005;46(12):2329-2334. [pmid: 16360067].
32 Cazeau S, Leclercq C, Lavergne T, et al. Effects of multisite biventricular pacing in patients with heart failure and intraventricular conduction delay. N Engl J Med. 2001;344(12):873-880. [pmid: 11259720].
33 Leclercq C, Walker S, Linde C, et al. Comparative effects of permanent biventricular and right-univentricular pacing in heart failure patients with chronic atrial fibrillation. Eur Heart J. 2002;23(22):1780-1787. [pmid: 12419298].
34 Abraham WT, Young JB, Leon AR, et al. Effects of cardiac resynchronization on disease progression in patients with left ventricular systolic dysfunction, an indication for an implantable cardioverter-defibrillator, and mildly symptomatic chronic heart failure. Circulation. 2004;110(18):2864-2868. [pmid: 15505095].
35 Cheng A, Gold MR, Waggoner AD, et al. Potential mechanisms underlying the effect of gender on response to cardiac resynchronization therapy: insights from the SMART-AV multicenter trial. Heart Rhythm. 2012;9(5):736-741. [pmid: 22182496].
36 Gold MR, Birgersdotter-Green U, Singh JP, et al. The relationship between ventricular electrical delay and left ventricular remodelling with cardiac resynchronization therapy. Eur Heart J. 2011;32(20):2516-2524. [pmid: 21875862].
37 Schuchert A, Muto C, Maounis T, et al. Lead complications, device infections, and clinical outcomes in the first year after implantation of cardiac resynchronization therapy-defibrillator and cardiac resynchronization therapy-pacemaker. Europace. 2013;15(1):71-76. [pmid: 22927665].
38 Diab IG, Hunter RJ, Kamdar R, et al. Does ventricular dyssynchrony on echocardiography predict response to cardiac resynchronisation therapy? A randomised controlled study. Heart. 2011;97(17):1410-1416. [pmid: 21700757].
39 Garikipati NV, Mittal S, Chaudhry F, et al. Comparison of endovascular versus epicardial lead placement for resynchronization therapy. Am J Cardiol. 2014;113(5):840-844. [pmid: 24406108].
40 Higgins SL, Hummel JD, Niazi IK, et al. Cardiac resynchronization therapy for the treatment of heart failure in patients with intraventricular conduction delay and malignant ventricular tachyarrhythmias. J Am Coll Cardiol. 2003;42(8):1454-1459. [pmid: 14563591].
41 Lozano I, Bocchiardo M, Achtelik M, et al. Impact of biventricular pacing on mortality in a randomized crossover study of patients with heart failure and ventricular arrhythmias. Pacing Clin Electrophysiol. 2000;23(11 Pt 2):1711-1712. [pmid: 11139906].
42 Pinter A, Mangat I, Korley V, et al. Assessment of resynchronization therapy on functional status and quality of life in patients requiring an implantable defibrillator. Pacing Clin Electrophysiol. 2009;32(12):1509-1519. [pmid: 19765233].
43 Pokushalov E, Romanov A, Prohorova D, et al. Coronary artery bypass grafting with concomitant cardiac resynchronisation therapy in patients with ischaemic heart failure and left ventricular dyssynchrony. Eur J Cardiothorac Surg. 2010;38(6):773-780. [pmid: 20447832].
44 Leclercq C, Cazeau S, Lellouche D, et al. Upgrading from single chamber right ventricular to biventricular pacing in permanently paced patients with worsening heart failure: The RD-CHF Study. Pacing Clin Electrophysiol. Suppl 1. 2007;30:S23-S30. [pmid: 17302711].
45 Auricchio A, Gold MR, Brugada J, et al. Long-term effectiveness of the combined minute ventilation and patient activity sensors as predictor of heart failure events in patients treated with cardiac resynchronization therapy: Results of the Clinical Evaluation of the Physiological Diagnosis Function in the PARADYM CRT device Trial (CLEPSYDRA) study. Eur J Heart Fail. 2014. [pmid: 24639140].
46 Azizi M, Castel MA, Behrens S, Rodiger W, Nagele H. Experience with coronary sinus lead implantations for cardiac resynchronization therapy in 244 patients. Herzschrittmacherther Elektrophysiol. 2006;17(1):13-18. [pmid: 16547655].
47 Bilchick KC, Kamath S, DiMarco JP, Stukenborg GJ. Bundle-branch block morphology and other predictors of outcome after cardiac resynchronization therapy in Medicare patients. Circulation. 2010;122(20):2022-2030. [pmid: 21041691].
48 Bossard M, Sticherling C, Kuhne M, Frey S, Osswald S, Schaer B. Outcome of patients with cardiac resynchronisation defibrillator therapy and a follow-up of at least five years after implant. Swiss Med Wkly. 2014;144:w13938. [pmid: 24573612].
49 Boven NV, Theuns D, Bogaard K, et al. Atrial Fibrillation in Cardiac Resynchronization Therapy with a Defibrillator: A Risk Factor for Mortality, Appropriate and Inappropriate Shocks. J Cardiovasc Electrophysiol. 2013. [pmid: 23889733].
50 Van Boven N, Bogaard K, Ruiter J, et al. Functional response to cardiac resynchronization therapy is associated with improved clinical outcome and absence of appropriate shocks. J Cardiovasc Electrophysiol. 2013;24(3):316-322. [pmid: 23210664].
51 de Cock CC, van Campen CM, Visser CA. Major dissection of the coronary sinus and its tributaries during lead implantation for biventricular stimulation: angiographic follow-up. Europace. 2004;6(1):43-47. [pmid: 14697725].
52 Duray GZ, Israel CW, Pajitnev D, Hohnloser SH. Upgrading to biventricular pacing/defibrillation systems in right ventricular paced congestive heart failure patients: prospective assessment of procedural parameters and response rate. Europace. 2008;10(1):48-52. [pmid: 18077483].
53 Gasparini M, Menozzi C, Proclemer A, et al. A simplified biventricular defibrillator with fixed long detection intervals reduces implantable cardioverter defibrillator (ICD) interventions and heart failure hospitalizations in patients with non-ischaemic cardiomyopathy implanted for primary prevention: the RELEVANT. Eur Heart J. 2009;30(22):2758-2767. [pmid: 19567380].
54 Gopalamurugan AB, Ganesha Babu G, Rogers DP, et al. Is CRT pro-arrhythmic? A comparative analysis of the occurrence of ventricular arrhythmias between patients implanted with CRTs and ICDs. Front Physiol. 2014;5:334. [pmid: 25278901].
55 Gras D, Leclercq C, Tang AS, Bucknall C, Luttikhuis HO, Kirstein-Pedersen A. Cardiac resynchronization therapy in advanced heart failure the multicenter InSync clinical study. Eur J Heart Fail. 2002;4(3):311-320. [pmid: 12034157].
56 Haugaa KH, Marek JJ, Ahmed M, et al. Mechanical dyssynchrony after cardiac resynchronization therapy for severely symptomatic heart failure is associated with risk for ventricular arrhythmias. J Am Soc Echocardiogr. 2014;27(8):872-879. [pmid: 24798865].
57 Niu HX, Hua W, Wang FZ, Zhang S, Chen KP, Chen X. Complications of cardiac resynchronization therapy in patients with congestive heart failure. Chin Med J (Engl). 2006;119(6):449-453. [pmid: 16584641].
58 Killu AM, Wu JH, Friedman PA, et al. Outcomes of cardiac resynchronization therapy in the elderly. Pacing Clin Electrophysiol. 2013;36(6):664-672. [pmid: 23252710].
59 Knight BP, Desai A, Coman J, Faddis M, Yong P. Long-term retention of cardiac resynchronization therapy. J Am Coll Cardiol. 2004;44(1):72-77. [pmid: 15234410].
60 Krahn AD, Snell L, Yee R, Finan J, Skanes AC, Klein GJ. Biventricular pacing improves quality of life and exercise tolerance in patients with heart failure and intraventricular conduction delay. Can J Cardiol. 2002;18(4):380-387. [pmid: 11992131].
61 Kuhlkamp V. Initial experience with an implantable cardioverter-defibrillator incorporating cardiac resynchronization therapy. J Am Coll Cardiol. 2002;39(5):790-797. [pmid: 11869843].
62 Landolina M, Gasparini M, Lunati M, et al. Long-term complications related to biventricular defibrillator implantation: rate of surgical revisions and impact on survival: insights from the Italian Clinical Service Database. Circulation. 2011;123(22):2526-2535. [pmid: 21576653].
63 Leong DP, Hoke U, Delgado V, et al. Right ventricular function and survival following cardiac resynchronisation therapy. Heart. 2013;99(10):722-728. [pmid: 23315608].
64 Mascioli G, Padeletti L, Sassone B, et al. Electrocardiographic criteria of true left bundle branch block: a simple sign to predict a better clinical and instrumental response to CRT. Pacing Clin Electrophysiol. 2012;35(8):927-934. [pmid: 22651702].
65 Masoudi FA, Mi X, Curtis LH, et al. Comparative effectiveness of cardiac resynchronization therapy with an implantable cardioverter-defibrillator versus defibrillator therapy alone: a cohort study. Ann Intern Med. 2014;160(9):603-611. [pmid: 24798523].
66 Mortensen PT, Sogaard P, Mansour H, et al. Sequential biventricular pacing: evaluation of safety and efficacy. Pacing Clin Electrophysiol. 2004;27(3):339-345. [pmid: 15009860].
67 Luo NS, Yuan WL, Lin YQ, et al. Potential proarrhythmic effect of cardiac resynchronization therapy during perioperative period: data from a single cardiac center. Chin Med J (Engl). 2010;123(17):2295-2298. [pmid: 21034537].
68 Niebauer MJ, Rickard J, Polakof L, Tchou PJ, Varma N. QRS frequency characteristics help predict response to cardiac resynchronization in left bundle branch block less than 150 milliseconds. Heart Rhythm. 2014. [pmid: 25068573].
69 Ricci RP, Pignalberi C, Landolina M, et al. Ventricular rate monitoring as a tool to predict and prevent atrial fibrillation-related inappropriate shocks in heart failure patients treated with cardiac resynchronisation therapy defibrillators. Heart. 2014;100(11):848-854. [pmid: 24682569].
70 Rickard J, Cheng A, Spragg D, et al. QRS narrowing is associated with reverse remodeling in patients with chronic right ventricular pacing upgraded to cardiac resynchronization therapy. Heart Rhythm. 2013;10(1):55-60. [pmid: 23000040].
71 Romeyer-Bouchard C, Da Costa A, Dauphinot V, et al. Prevalence and risk factors related to infections of cardiac resynchronization therapy devices. Eur Heart J. 2010;31(2):203-210. [pmid: 19875388].
72 Shanks M, Delgado V, Ng AC, et al. Clinical and echocardiographic predictors of nonresponse to cardiac resynchronization therapy. Am Heart J. 2011;161(3):552-557. [pmid: 21392611].
73 Shen X, Aronow WS, Holmberg MJ, et al. Cardiac resynchronization therapy in patients with intrinsic and right ventricular pacing-induced left bundle branch block pattern. Am J Ther. 2009;16(6):e44-e50. [pmid: 19940605].
74 Shen X, Aronow WS, Nair CK, et al. Are the extent, location, and score of segmental wall motion abnormalities related to cardiac resynchronization therapy response?. Echocardiography. 2009;26(10):1136-1145. [pmid: 19725853].
75 Shen X, Nair CK, Aronow WS, et al. A patient selection score for cardiac resynchronization therapy. Echocardiography. 2011;28(2):188-195. [pmid: 21276075].
76 Stabile G, Solimene F, Bertaglia E, et al. Long-term outcomes of CRT-PM versus CRT-D recipients. Pacing Clin Electrophysiol. Suppl 1. 2009;32:S141-S145. [pmid: 19250079].
77 Stahlberg M, Braunschweig F, Gadler F, Karlsson H, Linde C. Three year outcome of cardiac resynchronization therapy: a single center evaluation. Pacing Clin Electrophysiol. 2005;28(10):1013-1017. [pmid: 16221256].
78 Strimel W, Koplik S, Chen HR, Song J, Huang SK. Safety and effectiveness of primary prevention cardioverter defibrillators in octogenarians. Pacing Clin Electrophysiol. 2011;34(7):900-906. [pmid: 21438896].
79 Swindle JP, Rich MW, McCann P, Burroughs TE, Hauptman PJ. Implantable cardiac device procedures in older patients: use and in-hospital outcomes. Arch Intern Med. 2010;170(7):631-637. [pmid: 20386008].
80 Takaya Y, Noda T, Nakajima I, et al. Electrocardiographic predictors of response to cardiac resynchronization therapy in patients with intraventricular conduction delay. Circ. J. 2014;78(1):71-77. [pmid: 24162927].
81 Theuns DA, Thornton AS, Klootwijk AP, et al. Outcome in patients with an ICD incorporating cardiac resynchronisation therapy: differences between primary and secondary prophylaxis. Eur J Heart Fail. 2005;7(6):1027-1032. [pmid: 16109500].
82 Vado A, Menardi E, Rossetti G, Ballari G, Feola M, Bobbio M. Single-center experience of a quadripolar pacing lead for cardiac resynchronization therapy. J Interv Card Electrophysiol. 2014;39(2):161-165. [pmid: 24293178].
83 Verbrugge FH, De Vusser P, Rivero-Ayerza M, et al. Cardiac resynchronization therapy with or without defibrillator: experience from a high-volume Belgian implantation centre. Acta Cardiol. 2013;68(1):37-45. [pmid: 23457908].
84 Verbrugge FH, Dupont M, De Vusser P, et al. Response to cardiac resynchronization therapy in elderly patients (>/=70 years) and octogenarians. Eur J Heart Fail. 2013;15(2):203-210. [pmid: 23002114].
85 Wollmann CG, Lawo T, Kuhlkamp V, et al. Implantable defibrillators with enhanced detection algorithms: detection performance and safety results from the PainFree SST study. Pacing Clin Electrophysiol. 2014;37(9):1198-1209. [pmid: 24665992].
86 Zhang Q, van Bommel RJ, Fung JW, et al. Tissue Doppler velocity is superior to strain imaging in predicting long-term cardiovascular events after cardiac resynchronisation therapy. Heart. 2009;95(13):1085-1090. [pmid: 19363024].