# List of Excluded Studies

## Does not evaluate a CRT

Hoke U, Auger D, Thijssen J, Wolterbeek R, van der Velde ET, Holman ER, Schalij MJ, Bax JJ, Delgado V, Marsan NA. Significant lead-induced tricuspid regurgitation is associated with poor prognosis at long-term follow-up. Heart. 2014.
Kobe J, Wasmer K, Andresen D, Kleemann T, Spitzer SG, Jehle J, Brachmann J, Stellbrink C, Hochadel M, Senges J, Klein HU, Eckardt L. Impact of atrial fibrillation on early complications and one year-survival after cardioverter defibrillator implantation: results from the German DEVICE registry. Int J Cardiol. 2013:4184-4190. [pmid: 23948108].
Peterson PN, Varosy PD, Heidenreich PA, Wang Y, Dewland TA, Curtis JP, Go AS, Greenlee RT, Magid DJ, Normand SL, Masoudi FA. Association of single- vs dual-chamber ICDs with mortality, readmissions, and complications among patients receiving an ICD for primary prevention. JAMA. 2013:2025-2034. [pmid: 23677314].
Angheloiu GO, Saul M, Edelman K, Shah H, Mezu UL, Saba S. Predictors of left ventricular function deterioration in patients with left bundle branch block and ejection fraction &gt;50%. Congest Heart Fail. 2013:E1-E4. [pmid: 23586729].
Oh C, Chang HJ, Sung JM, Kim JY, Yang W, Shim J, Kang SM, Ha J, Rim SJ, Chung N. Prognostic Estimation of Advanced Heart Failure With Low Left Ventricular Ejection Fraction and Wide QRS Interval. Korean Circ J. 2012:659-667. [pmid: 23170093].
Fonarow GC, Albert NM, Curtis AB, Gheorghiade M, Liu Y, Mehra MR, O'Connor CM, Reynolds D, Walsh MN, Yancy CW. Incremental Reduction in Risk of Death Associated With Use of Guideline-Recommended Therapies in Patients With Heart Failure: A Nested Case-Control Analysis of IMPROVE HF. J Am Heart Assoc. 2012:16-26. [pmid: 23130115].
Reithmann C, Herkommer B, Huemmer A, von Hoch F, Fiek M. The risk of delayed atrioventricular and intraventricular conduction block following ablation of bundle branch reentry. Clin Res Cardiol. 2013:145-153. [pmid: 23015015].
Malecka B, Zabek A, Maziarz A, Lelakowski J. Influence of heart failure etiology on the effect of upgrading from right ventricular apical to biventricular or bifocal pacing in patients with permanent atrial fibrillation and advanced heart failure. Pol Arch Med Wewn. 2012:89-97. [pmid: 22415222].
Stabile G, D'Agostino C, Gallo P, Marrazzo N, Iuliano A, De Simone A, Turco P, Palella M, Donnici G, Ciardiello C, Napolitano G, Solimene F. Appropriate therapies predict long-term mortality in primary and secondary prevention of sudden cardiac death. J Cardiovasc Med (Hagerstown). 2013:110-113. [pmid: 22367567].
Biasucci LM, Bellocci F, Landolina M, Rordorf R, Vado A, Menardi E, Giubilato G, Orazi S, Sassara M, Castro A, Massa R, Kheir A, Zaccone G, Klersy C, Accardi F, Crea F. Risk stratification of ischaemic patients with implantable cardioverter defibrillators by C-reactive protein and a multi-markers strategy: results of the CAMI-GUIDE study. Eur Heart J. 2012:1344-1350. [pmid: 22285581].
Greenspon AJ, Patel JD, Lau E, Ochoa JA, Frisch DR, Ho RT, Pavri BB, Kurtz SM. 16-year trends in the infection burden for pacemakers and implantable cardioverter-defibrillators in the United States 1993 to 2008. J Am Coll Cardiol. 2011:1001-1006. [pmid: 21867833].
Barsheshet A, Goldenberg I, Moss AJ, Huang DT, Zareba W, McNitt S, Klein HU, Guetta V. Effect of elapsed time from coronary revascularization to implantation of a cardioverter defibrillator on long-term survival in the MADIT-II trial. J Cardiovasc Electrophysiol. 2011:1237-1242. [pmid: 21615813].
Chen TB, Cheng KA, Gao P, Cheng ZW, Fan JB, Jiang XC, Fang Q. Primary prevention of sudden cardiac death by implantable cardioverter-defibrillator therapy in Chinese patients with heart failure: a single-center experience. Chin Med J (Engl). 2010:848-851. [pmid: 20497676].
Agha SA, Kalogeropoulos AP, Shih J, Georgiopoulou VV, Giamouzis G, Anarado P, Mangalat D, Hussain I, Book W, Laskar S, Smith AL, Martin R, Butler J. Echocardiography and risk prediction in advanced heart failure: incremental value over clinical markers. J Card Fail. 2009:586-592. [pmid: 19700135].
Soliman OI, van Dalen BM, Nemes A, Zwaan HB, Vletter WB, ten Cate FJ, Theuns DA, Jordaens LJ, Geleijnse ML. Quantification of left ventricular systolic dyssynchrony by real-time three-dimensional echocardiography. J Am Soc Echocardiogr. 2009:232-239. [pmid: 19101112].
Fazelifar AF, Bonakdar HR, Alizadeh K, Azarnik H, Haghjoo M, Abkenar HB, Samiei N, Sadr-Ameli MA. Relationship between QRS complex notch and ventricular dyssynchrony in patients with heart failure and prolonged QRS duration. Cardiol J. 2008:351-356. [pmid: 18698544].
Swindle J, Burroughs TE, Schnitzler MA, Hauptman PJ. Short-term mortality and cost associated with cardiac device implantation in patients hospitalized with heart failure. Am Heart J. 2008:322-328. [pmid: 18657663].
van Eck JW, van Hemel NM, Zuithof P, van Asseldonk JP, Voskuil TL, Grobbee DE, Moons KG. Incidence and predictors of in-hospital events after first implantation of pacemakers. Europace. 2007:884-889. [pmid: 17556376].
Hirschl DA, Jain VR, Spindola-Franco H, Gross JN, Haramati LB. Prevalence and characterization of asymptomatic pacemaker and ICD lead perforation on CT. Pacing Clin Electrophysiol. 2007:28-32. [pmid: 17241311].
Mansour M, Rasche V, Picard MH, Ruskin JN. Integration of three-dimensional coronary venous angiography with three-dimensional echocardiography for biventricular device implantation. Heart Rhythm. 2006:1391-1392. [pmid: 17074653].
O'Connell JW, Schreck C, Moles M, Badwar N, DeMarco T, Olgin J, Lee B, Tseng Z, Kumar U, Botvinick EH. A unique method by which to quantitate synchrony with equilibrium radionuclide angiography. J Nucl Cardiol. 2005:441-450. [pmid: 16084433].
Toff WD, Camm AJ, Skehan JD. Single-chamber versus dual-chamber pacing for high-grade atrioventricular block. N Engl J Med. 2005:145-155. [pmid: 16014884].
Bardy GH, Lee KL, Mark DB, Poole JE, Packer DL, Boineau R, Domanski M, Troutman C, Anderson J, Johnson G, McNulty SE, Clapp-Channing N, Davidson-Ray LD, Fraulo ES, Fishbein DP, Luceri RM, Ip JH. Amiodarone or an implantable cardioverter-defibrillator for congestive heart failure. N Engl J Med. 2005:225-237. [pmid: 15659722].
da Silva Menezes A. Outcome of right ventricular bifocal pacing in patients with permanent atrial fibrillation and severe dilated cardiomiopathy due to Chagas disease: three years of follow-up. J Interv Card Electrophysiol. 2004:193-198. [pmid: 15548885].
Bleeker GB, Schalij MJ, Molhoek SG, Verwey HF, Holman ER, Boersma E, Steendijk P, Van Der Wall EE, Bax JJ. Relationship between QRS duration and left ventricular dyssynchrony in patients with end-stage heart failure. J Cardiovasc Electrophysiol. 2004:544-549. [pmid: 15149423].
Kang SJ, Song JK, Yang HS, Song JM, Kang DH, Rhee KS, Nam GB, Choi KJ, Kim JJ, Kim YH. Systolic and diastolic regional myocardial motion of pacing-induced versus idiopathic left bundle branch block with and without left ventricular dysfunction. Am J Cardiol. 2004:1243-1246. [pmid: 15135697].
Stolen KQ, Kemppainen J, Kalliokoski KK, Hallsten K, Luotolahti M, Karanko H, Lehikoinen P, Viljanen T, Salo T, Airaksinen KE, Nuutila P, Knuuti J. Myocardial perfusion reserve and oxidative metabolism contribute to exercise capacity in patients with dilated cardiomyopathy. J Card Fail. 2004:132-140. [pmid: 15101025].
Makaryus AN, Arduini AD, Mallin J, Chung E, Kort S, Shi Q, Jadonath R, Mangion J. Echocardiographic features of patients with heart failure who may benefit from biventricular pacing. Echocardiography. 2003:217-223. [pmid: 12848658].
Thackray SD, Witte KK, Nikitin NP, Clark AL, Kaye GC, Cleland JG. The prevalence of heart failure and asymptomatic left ventricular systolic dysfunction in a typical regional pacemaker population. Eur Heart J. 2003:1143-1152. [pmid: 12804929].
Galizio NO, Pesce R, Valero E, Gonzalez JL, Favaloro RR, Favaloro L, Perrone S, Davila P, Godoy M. Which patients with congestive heart failure may benefit from biventricular pacing?. Pacing Clin Electrophysiol. 2003:158-161. [pmid: 12687804].
Grimm W, Sharkova J, Funck R, Maisch B. How many patients with dilated cardiomyopathy may potentially benefit from cardiac resynchronization therapy?. Pacing Clin Electrophysiol. 2003:155-157. [pmid: 12687803].
Erdogan A, Rueckleben S, Tillmanns HH, Waldecker B. Proportion of candidates for cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2003:152-154. [pmid: 12687802].
Moss AJ, Daubert J, Zareba W. MADIT-II: clinical implications. Card Electrophysiol Rev. 2002:463-465. [pmid: 12438829].
Pyatt JR, Somauroo JD, Jackson M, Grayson AD, Osula S, Aggarwal RK, Charles RG, Connelly DT. Long-term survival after permanent pacemaker implantation: analysis of predictors for increased mortality. Europace. 2002:113-119. [pmid: 12135241].
Lamas GA, Lee KL, Sweeney MO, Silverman R, Leon A, Yee R, Marinchak RA, Flaker G, Schron E, Orav EJ, Hellkamp AS, Greer S, McAnulty J, Ellenbogen K, Ehlert F, Freedman RA, Estes NA 3rd, Greenspon A, Goldman L. Ventricular pacing or dual-chamber pacing for sinus-node dysfunction. N Engl J Med. 2002:1854-1862. [pmid: 12063369].
Werling C, Weisse U, Siemon G, Kiessling AH, Rameken M, Schwacke H, Saggau W, Senges J, Seidl K. Biventricular pacing in patients with ICD: how many patients are possible candidates?. Thorac Cardiovasc Surg. 2002:67-70. [pmid: 11981703].
Tepper D. Frontiers in congestive heart failure: initial experience with an implantable cardioverter-defibrillator incorporating cardiac resynchronization therapy. Congest Heart Fail. 2002:91. [pmid: 11927784].
Uebleis C, Hellweger S, Laubender RP, Becker A, Sohn H-Y, Lehner S, Haug A, Bartenstein P, Cumming P, Van Kriekinge SD, Slomka PJ, Hacker M. Left ventricular dyssynchrony assessed by gated SPECT phase analysis is an independent predictor of death in patients with advanced coronary artery disease and reduced left ventricular function not undergoing cardiac resynchronization therapy. Eur. J. Nucl. Med. Mol. Imaging. 2012:1561-1569. [pmid: 22752450].
Holman WL, Kirklin JK, Naftel DC, Kormos RL, Desvign-Nickens P, Camacho MT, Ascheim DD. Infection after implantation of pulsatile mechanical circulatory support devices. J. Thorac. Cardiovasc. Surg. 2010:1632-1636.e2. [pmid: 20363482].
Liu X, Yu H, Pei J, Chu J, Pu J, Zhang S. Clinical Characteristics and Long-term Prognosis in Patients with Chronic Heart Failure and Reduced Ejection Fraction in China. Heart Lung Circul. 2014.
Marynissen T, Flore V, Heidbuchel H, Nuyens D, Ector J, Willems R. Heart rate turbulence predicts ICD-resistant mortality in ischaemic heart disease. Europace. 2014:1069-1077. [pmid: 24196450].
Verhagen MP, van Boven N, Ruiter JH, Kimman GJ, Tahapary GJ, Umans VA. Follow-up of implantable cardioverter-defibrillator therapy: comparison of coronary artery disease and dilated cardiomyopathy. Neth Heart J. 2014:431-437. [pmid: 25169578].
Gierula J, Cubbon RM, Jamil HA, Byrom RJ, Waldron ZL, Pavitt S, Kearney MT, Witte KK. Patients with long-term permanent pacemakers have a high prevalence of left ventricular dysfunction. J Cardiovasc Med (Hagerstown). 2014.
Al-Khatib SM, Hellkamp AS, Fonarow GC, Mark DB, Curtis LH, Hernandez AF, Anstrom KJ, Peterson ED, Sanders GD, Al-Khalidi HR, Hammill BG, Heidenreich PA, Hammill SC. Association between prophylactic implantable cardioverter-defibrillators and survival in patients with left ventricular ejection fraction between 30% and 35%. JAMA. 2014:2209-2215. [pmid: 24893088].
Jimenez-Candil J, Morinigo JL, Hernandez J, Martin A, Duran O, Carlos Rama J, Ledesma C, Sanchez PL. Fragmentation of the Paced QRS Complex: A Marker of Antitachycardia Pacing Effectiveness Among ICD Patients. J Cardiovasc Electrophysiol. 2014:1100-1108. [pmid: 24816219].
Eisen A, Suleiman M, Strasberg B, Sela R, Rosenheck S, Freedberg NA, Geist M, Ben-Zvi S, Goldenberg I, Glikson M, Haim M. Renal Dysfunction and Clinical Outcomes of Patients Undergoing ICD and CRTD Implantation: Data from the Israeli ICD Registry. J Cardiovasc Electrophysiol. 2014:990-997. [pmid: 24761993].
Fishbein DP, Hellkamp AS, Mark DB, Walsh MN, Poole JE, Anderson J, Johnson G, Lee KL, Bardy GH. Use of the 6-min walk distance to identify variations in treatment benefits from implantable cardioverter-defibrillator and amiodarone: results from the SCD-HeFT (Sudden Cardiac Death in Heart Failure Trial). J Am Coll Cardiol. 2014:2560-2568. [pmid: 24727258].
Roger S, Schneider R, Rudic B, Liebe V, Stach K, Schimpf R, Borggrefe M, Kuschyk J. Cardiac contractility modulation: first experience in heart failure patients with reduced ejection fraction and permanent atrial fibrillation. Europace. 2014:1205-1209. [pmid: 24706089].
Shalaby AA, Brumberg GE, Pointer L, Bekelman DB, Rumsfeld JS, Yang Y, Pellegrini CN, Heidenreich PA, Keung E, Massie BM, Varosy PD. Depression and outcome among veterans with implantable cardioverter defibrillators with or without cardiac resynchronization therapy capability. Pacing Clin Electrophysiol. 2014:994-1001. [pmid: 24520992].

## No Original Data

Earley A, Persson R, Garlitski AC, Balk EM, Uhlig K. Effectiveness of implantable cardioverter defibrillators for primary prevention of sudden cardiac death in subgroups a systematic review. Ann Intern Med. 2014:111-121. [pmid: 24592496].
Biventricular pacing for adults with AV block and heart failure. BMJ. 2013:f2719. [pmid: 23637151].
Krum H, Lemke B, Birnie D, Lee KL, Aonuma K, Starling RC, Gasparini M, Gorcsan J, Rogers T, Sambelashvili A, Kalmes A, Martin D. A novel algorithm for individualized cardiac resynchronization therapy: rationale and design of the adaptive cardiac resynchronization therapy trial. Am Heart J. 2012:747-752.e1. [pmid: 22607850].
Klein HU. Preventive cardiac resynchronisation therapy. Heart. 2012:508-515. [pmid: 22350030].
Holzmeister J, Abraham WT. Device therapy: Indications for ICD-CRT in mildly symptomatic heart failure. Nat Rev Cardiol. 2010:7-8. [pmid: 20019754].
St John Sutton M. Cardiac resynchronization therapy and reduced risk of death and nonfatal heart failure events. Curr Heart Fail Rep. 2009:211-212. [pmid: 19948088].
Breithardt G. MADIT-CRT (Multicenter Automatic Defibrillator Implantation Trial-Cardiac Resynchronization Therapy): cardiac resynchronization therapy towards early management of heart failure. Eur Heart J. 2009:2551-2553. [pmid: 19773224].
Prinzen FW, Auricchio A. Is echocardiographic assessment of dyssynchrony useful to select candidates for cardiac resynchronization therapy? Echocardiography is not useful before cardiac resynchronization therapy if QRS duration is available. Circ Cardiovasc Imaging. 2008:70-77. discussion 78. [pmid: 19808516].
Shalaby A, Voigt A, El-Saed A, Saba S. Usefulness of pulmonary artery pressure by echocardiography to predict outcome in patients receiving cardiac resynchronization therapy heart failure. Am J Cardiol. 2008:238-241. [pmid: 18178413].
Nagele H, Behrens S, Azizi M. What can happen during coronary sinus lead implantation: dislocation, perforation and other catastrophes. Herzschrittmacherther Elektrophysiol. 2007:243-249. [pmid: 18084798].
Yu CM, Abraham WT, Bax J, Chung E, Fedewa M, Ghio S, Leclercq C, Leon AR, Merlino J, Nihoyannopoulos P, Notabartolo D, Sun JP, Tavazzi L. Predictors of response to cardiac resynchronization therapy (PROSPECT)--study design. Am Heart J. 2005:600-605. [pmid: 15990740].
Moss AJ, Daubert J, Zareba W. MADIT-II: clinical implications. Card Electrophysiol Rev. 2002:463-465. [pmid: 12438829].
Tepper D. Frontiers in congestive heart failure: Ventricular contraction abnormalities in dilated cardiomyopathy: effect of biventricular pacing to correct interventricular dyssynchrony. Congest Heart Fail. 2000:224. [pmid: 12147958].
A double jolt for heart failure. Harv Heart Lett. 2002:5-6.
Rodriguez Y, Garisto J, Carrillo RG. Management of cardiac device-related infections: A review of protocol-driven care. Int. J. Cardiol. 2013:55-60. [pmid: 22033126].
Chen S, Yin Y, Krucoff MW. Effect of cardiac resynchronization therapy and implantable cardioverter defibrillator on quality of life in patients with heart failure: A meta-analysis. Europace. 2012:1602-1607. [pmid: 23104857].
Liang Y, Pan W, Su Y, Ge J. Meta-analysis of randomized controlled trials comparing isolated left ventricular and biventricular pacing in patients with chronic heart failure. Am. J. Cardiol. 2011:1160-1165. [pmid: 21813108].
King A. Heart failure: Cardiac device therapy in elderly patientsinsights from 'real world' practice. Nat. Rev. Cardiol. 2010:357. [pmid: 20589997].
Resynchronization therapy in patients with narrow QRS (RethinQ). ACC Cardiosource Rev. J. 2007:30.
Fusco A. NYHA functional class IV patients: Cardiac Resynchronization therapy with defibrillator back up. Mediterr. J. Pacing Electrophysiol. 2007:106-108.
Saxon LA. Does cardiac resynchronization therapy reduce the incidence of atrial fibrillation, and does atrial fibrillation compromise the cardiac resynchronization therapy effect?. Heart Rhythm. 2007:S31-S33. [pmid: 17336881].
Auricchio A, Klein HU. Expansion of ICD indications: Resynchronization therapy and the ICD. Card. Electrophysiol. Rev. 2001:35-40.
Ricci R, Ansalone G, Toscano S, Pignalberi C, Lunati M, Gasparini M, Padeletti L, Disertori M, Ravazzi PA, Santini M. Cardiac resynchronization: Materials, technique and results. The InSync Italian Registry. Eur. Heart. J. Suppl. 2000:J6-J15.
Steffel J, Ruschitzka F. Superresponse to cardiac resynchronization therapy. Circulation. 2014:87-90. [pmid: 24982120].

## Not in English

Pires R, Elvas L, Monteiro P, Cristovao J, Antunes A, Ventura M, Costa M, Ermida P, Providencia LA. Biventricular pacing--early experience. Rev Port Cardiol. 2001:1235-1239. [pmid: 11865683].
Barretto RBM, Piegas LS, Assef JE, Melo Neto JF, Resende TU, Moreira DA, Lebihan DC, Franca FF, Meneghelo RS, Sousa AGMR. Mechanical dyssynchrony is similar in different patterns of left bundle-branch block: A dissincronia mecanica e semelhante em diferentes padroes do bloqueio de ramo esquerdo. Arq. Bras. Cardiol. 2013:449-455. [pmid: 24061684].

## No full report

St John Sutton M. Cardiac resynchronization therapy and reduced risk of death and nonfatal heart failure events. Curr Heart Fail Rep. 2009:211-212. [pmid: 19948088].
Yu CM, Lin H, Fung WH, Zhang Q, Kong SL, Sanderson JE. Comparison of acute changes in left ventricular volume, systolic and diastolic functions, and intraventricular synchronicity after biventricular and right ventricular pacing for heart failure. Am Heart J. 2003:E18. [pmid: 12766742].
Tepper D. Frontiers in congestive heart failure: Ventricular contraction abnormalities in dilated cardiomyopathy: effect of biventricular pacing to correct interventricular dyssynchrony. Congest Heart Fail. 2000:224. [pmid: 12147958].
Tepper D. Frontiers in congestive heart failure: initial experience with an implantable cardioverter-defibrillator incorporating cardiac resynchronization therapy. Congest Heart Fail. 2002:91. [pmid: 11927784].
Sepsi M, Krivan L, Koza KM, Sebo M, Poloczek M, Jarkovsky J, Rybka L, Kubkova L, Vlasinova J, Spinar J. Optimization of cardiac resynchronization therapy in non-responders. Cor Vasa. 2013:E293-E300.
Harris S, Tepper D, Ip R. Comparison of the Effects of Cardiac Resynchronization Therapy in Patients With Class II vs Class III and IV Heart Failure (From the InSync/InSync ICD Italian Registry). Congestive Heart Fail. 2013.

## Not relevant to Key Questions

Killu AM, Grupper A, Friedman PA, Powell BD, Asirvatham SJ, Espinosa RE, Luria D, Rozen G, Buber Y, Lee YH, Webster T, Brooke KL, Hodge DO, Wiste HJ, Glikson M, Cha YM. Predictors and Outcomes of 'Super-Response' to Cardiac Resynchronization Therapy. J Card Fail. 2014.
Gasparini M, Leclercq C, Lunati M, Landolina M, Auricchio A, Santini M, Boriani G, Lamp B, Proclemer A, Curnis A, Klersy C, Leyva F. Cardiac Resynchronization Therapy in Patients With Atrial Fibrillation: The CERTIFY Study (Cardiac Resynchronization Therapy in Atrial Fibrillation Patients Multinational Registry). JACC Heart Fail. 2013:500-507. [pmid: 24622002].
Ma CY, Liu S, Yang J, Tang L, Zhang LM, Li N, Yu B. Evaluation of Global Longitudinal Strain of Left Ventricle and Regional Longitudinal Strain in the Region of Left Ventricular Leads Predicts the Response to Cardiac Resynchronization Therapy in Patients with Ischemic Heart Failure. Cell Biochem Biophys. 2014.
Lin X, Xu H, Zhao X, Chen J. Sites of latest mechanical activation as assessed by SPECT myocardial perfusion imaging in ischemic and dilated cardiomyopathy patients with LBBB. Eur J Nucl Med Mol Imaging. 2014.
Gabrielli L, Marincheva G, Bijnens B, Doltra A, Tolosana JM, Borras R, Castel MA, Berruezo A, Brugada J, Mont L, Sitges M. Septal flash predicts cardiac resynchronization therapy response in patients with permanent atrial fibrillation. Europace. 2014.
Wilton SB, Exner DV, Healey JS, Birnie D, Arnold MO, Sapp JL, Thibault B, Simpson CS, Tung S, Crystal E, Sivakumaran S, Khaykin Y, Yetisir E, Wells G, Tang AS. Left Ventricular Lead Position and Outcomes in the Resynchronization-Defibrillation for Ambulatory Heart Failure Trial (RAFT). Can J Cardiol. 2013.
Amit G, Suleiman M, Konstantino Y, Luria D, Kazatsker M, Chetboun I, Haim M, Gavrielov-Yusim N, Goldenberg I, Glikson M. Sex differences in implantable cardioverter-defibrillator implantation indications and outcomes: lessons from the Nationwide Israeli-ICD Registry. Europace. 2014.
Sohinki D, Ho J, Srinivasan N, Collins LJ, Obel OA. Outcomes after atrioventricular node ablation and biventricular pacing in patients with refractory atrial fibrillation and heart failure: a comparison between non-ischaemic and ischaemic cardiomyopathy. Europace. 2014.
Conraads VM, Spruit MA, Braunschweig F, Cowie MR, Tavazzi L, Borggrefe M, Hill MR, Jacobs S, Gerritse B, van Veldhuisen DJ. Physical activity measured with implanted devices predicts patient outcome in chronic heart failure. Circ Heart Fail. 2014:279-287. [pmid: 24519908].
Marechaux S, Guiot A, Castel AL, Guyomar Y, Semichon M, Delelis F, Heuls S, Ennezat PV, Graux P, Tribouilloy C. Relationship between Two-Dimensional Speckle-Tracking Septal Strain and Response to Cardiac Resynchronization Therapy in Patients with Left Ventricular Dysfunction and Left Bundle Branch Block: A Prospective Pilot Study. J Am Soc Echocardiogr. 2014.
Sardu C, Marfella R, Santulli G. Impact of Diabetes Mellitus on the Clinical Response to Cardiac Resynchronization Therapy in Elderly People. J Cardiovasc Transl Res. 2014.
Small RS, Whellan DJ, Boyle A, Sarkar S, Koehler J, Warman EN, Abraham WT. Implantable device diagnostics on day of discharge identify heart failure patients at increased risk for early readmission for heart failure. Eur J Heart Fail. 2013.
Daya HA, Alam MB, Adelstein E, Schwartzman D, Jain S, Marek J, Gorcsan J, Saba S. Echocardiography-guided left ventricular lead placement for cardiac resynchronization therapy in ischemic vs nonischemic cardiomyopathy patients. Heart Rhythm. 2014:614-619. [pmid: 24462657].
Auger D, Hoke U, Thijssen J, Abate E, Yiu KH, Ewe SH, Witkowski TG, Leong DP, Holman ER, Ajmone Marsan N, Schalij MJ, Bax JJ, Delgado V. Effect of cardiac resynchronization therapy on the sequence of mechanical activation assessed by two-dimensional radial strain imaging. Am J Cardiol. 2014:982-987. [pmid: 24462070].
Mizia-Stec K, Wita K, Mizia M, Szwed H, Nowalany-Kozielska E, Chrzanowski L, Loboz-Grudzien K, Gackowski A, Gilewski W, Chmiel A, Sicari R, Plonska-Gosciniak E. Preserved contractile reserve in a dobutamine test for the prediction of a response to resynchronisation therapy in ischaemic and non-ischaemic cardiomyopathy - A multicenter ViaCRT study. Int J Cardiol. 2014:476-477. [pmid: 24456874].
Antonio N, Soares A, Carvalheiro T, Fernandes R, Paiva A, Ventura M, Cristovao J, Elvas L, Goncalves L, Providencia LA, Fontes Ribeiro C, Mariano Pego G. Circulating Endothelial Progenitor Cells as a Predictor of Response to Cardiac Resynchronization Therapy: The Missing Piece of the Puzzle?. Pacing Clin Electrophysiol. 2014.
Fujiwara R, Yoshida A, Fukuzawa K, Takei A, Kiuchi K, Itoh M, Imamura K, Suzuki A, Nakanishi T, Yamashita S, Matsumoto A, Tanaka H, Hirata KI. Discrepancy between Electrical and Mechanical Dyssynchrony in Patients with Heart Failure and an Electrical Disturbance. Pacing Clin Electrophysiol. 2013.
Aktas MK, Zareba W, Huang DT, McNitt S, Polonsky S, Chen L, Stockburger M, Merkely B, Moss AJ, Kutyifa V. The Effect of Weight Loss on Clinical Outcomes in Patients Implanted With a Cardiac Resynchronization Therapy Device-A MADIT-CRT Substudy. J Card Fail. 2014:183-189. [pmid: 24361804].
Kuperstein R, Goldenberg I, Moss AJ, Solomon S, Bourgoun M, Shah A, McNitt S, Zareba W, Klempfner R. Left atrial volume and the benefit of cardiac resynchronization therapy in the MADIT-CRT trial. Circ Heart Fail. 2014:154-160. [pmid: 24347664].
Fabregat-Andres O, Garcia-Gonzalez P, Valle-Munoz A, Estornell-Erill J, Perez-Bosca L, Palanca-Gil V, Paya-Serrano R, Quesada-Dorador A, Morell S, Ridocci-Soriano F. Clinical Benefit of Cardiac Resynchronization Therapy With a Defibrillator in Patients With an Ejection Fraction &gt;35% Estimated by Cardiac Magnetic Resonance. Rev Esp Cardiol. 2014:107-113. [pmid: 24795117].
Zecchin M, Proclemer A, Magnani S, Vitali-Serdoz L, Facchin D, Muser D, Nordio A, Barbati G, Puggia I, Sinagra G, Proclemer A. Long-term outcome of 'super-responder' patients to cardiac resynchronization therapy. Europace. 2014:363-371. [pmid: 24189477].
Schaer BA, Hitz L, Sticherling C, Kuhne M, Dickenmann M, Jordaens M, Osswald L, Theuns S. Changes in renal function over time in patients with cardiac resynchronisation therapy. Swiss Med Wkly. 2013:w13863. [pmid: 24163096].
Hsu JC, Varosy PD, Bao H, Dewland TA, Curtis JP, Marcus GM. Cardiac perforation from implantable cardioverter-defibrillator lead placement: insights from the national cardiovascular data registry. Circ Cardiovasc Qual Outcomes. 2013:582-590. [pmid: 24002030].
Kobe J, Wasmer K, Andresen D, Kleemann T, Spitzer SG, Jehle J, Brachmann J, Stellbrink C, Hochadel M, Senges J, Klein HU, Eckardt L. Impact of atrial fibrillation on early complications and one year-survival after cardioverter defibrillator implantation: results from the German DEVICE registry. Int J Cardiol. 2013:4184-4190. [pmid: 23948108].
Kiani J, Agarwal SK, Kamireddy S, Adelstein E, Saba S. Relationship of electro-mechanical remodeling to survival rates after cardiac resynchronization therapy. Tex Heart Inst J. 2013:268-273. [pmid: 23914016].
Yamamoto T, Shimano M, Inden Y, Miyata S, Inoue Y, Yoshida N, Tsuji Y, Hirai M, Murohara T. Cystatin C as a predictor of mortality and cardiovascular morbidity after cardiac resynchronization therapy. Circ J. 2013:2751-2756. [pmid: 23912790].
Agacdiken A, Celikyurt U, Sahin T, Karauzum K, Vural A, Ural D. Neutrophil-to-lymphocyte ratio predicts response to cardiac resynchronization therapy. Med Sci Monit. 2013:373-377. [pmid: 23686301].
Hernandez Madrid A, Matia Frances R, Moro C, Zamorano J. Cardiac resynchronization therapy: do patient selection and implant practice vary depending on the volume a center handles?. Pacing Clin Electrophysiol. 2013:863-871. [pmid: 23594313].
Sherry D, Knight BP, Casey C, Larson J, Hacker ED, Quinn LT, Wang E, Collins EG. A pilot study evaluating daily physical activity before and after cardiac resynchronization therapy. Biol Res Nurs. 2014:31-37. [pmid: 23539670].
Ruwald MH, Ruwald AC, Jons C, Alexis J, McNitt S, Zareba W, Moss AJ. Effect of metoprolol versus carvedilol on outcomes in MADIT-CRT (multicenter automatic defibrillator implantation trial with cardiac resynchronization therapy). J Am Coll Cardiol. 2013:1518-1526. [pmid: 23500269].
Boidol J, Sredniawa B, Kowalski O, Szulik M, Mazurek M, Sokal A, Pruszkowska-Skrzep P, Kukulski T, Kalarus Z, Lenarczyk R. Many response criteria are poor predictors of outcomes after cardiac resynchronization therapy: validation using data from the randomized trial. Europace. 2013:835-844. [pmid: 23487543].
Knappe D, Pouleur AC, Shah AM, Bourgoun M, Brown MW, Foster E, Pfeffer MA, Moss AJ, Solomon SD. Acute effects of withdrawal of cardiac resynchronization therapy on left and right ventricular function, dyssynchrony, and contractile function in patients with New York Heart Association functional class I/II heart failure: MADIT-CRT. J Card Fail. 2013:149-155. [pmid: 23482074].
Kydd AC, Khan FZ, O'Halloran D, Pugh PJ, Virdee MS, Dutka DP. Radial strain delay based on segmental timing and strain amplitude predicts left ventricular reverse remodeling and survival after cardiac resynchronization therapy. Circ Cardiovasc Imaging. 2013:177-184. [pmid: 23363579].
Vaillant C, Martins RP, Donal E, Leclercq C, Thebault C, Behar N, Mabo P, Daubert JC. Resolution of left bundle branch block-induced cardiomyopathy by cardiac resynchronization therapy. J Am Coll Cardiol. 2013:1089-1095. [pmid: 23352778].
Praus R, Haman L, Tauchman M, Pudil R, Blaha V, Parizek P. Echocardiographic changes after cardiac resynchronisation therapy. Kardiol Pol. 2012:1250-1257. [pmid: 23264243].
Brenyo A, Rao M, Barsheshet A, Cannom D, Quesada A, McNitt S, Huang DT, Moss AJ, Zareba W. QRS axis and the benefit of cardiac resynchronization therapy in patients with mildly symptomatic heart failure enrolled in MADIT-CRT. J Cardiovasc Electrophysiol. 2013:442-448. [pmid: 23252875].
Xu GJ, Gan TY, Tang BP, Ma YT, Zhang Y, Li JX, Zhang YY, Wang J, Tang Q, Wang CM, Li YD, Zhang JH. Predictive factors and clinical effect of optimized cardiac resynchronization therapy. Exp Ther Med. 2013:355-361. [pmid: 23251298].
Perrotta L, Xhaferi B, Chiostri M, Pieragnoli P, Ricciardi G, Di Biase L, Natale A, Ricceri I, Biria M, Lakkireddy D, Valleggi A, Emdin M, Michelotti F, Mascioli G, Pandozi A, Santini M, Padeletti L. Effects of smoking in patients treated with cardiac resynchronization therapy. Intern Emerg Med. 2014:311-318. [pmid: 23250544].
Hoke U, Thijssen J, van Bommel RJ, van Erven L, van der Velde ET, Holman ER, Schalij MJ, Bax JJ, Delgado V, Marsan NA. Influence of diabetes on left ventricular systolic and diastolic function and on long-term outcome after cardiac resynchronization therapy. Diabetes Care. 2013:985-991. [pmid: 23223348].
Chan YH, Wu LS, Kuo CT, Wang CL, Yeh YH, Ho WJ, Hsu LA. Incremental value of inefficient deformation indices for predicting response to cardiac resynchronization therapy. J Am Soc Echocardiogr. 2013:307-315. [pmid: 23218965].
de Roest GJ, Allaart CP, Kleijn SA, Delnoy PP, Wu L, Hendriks ML, Bronzwaer JG, van Rossum AC, de Cock CC. Prediction of long-term outcome of cardiac resynchronization therapy by acute pressure-volume loop measurements. Eur J Heart Fail. 2013:299-307. [pmid: 23183349].
Eickholt C, Siekiera M, Kirmanoglou K, Rodenbeck A, Heussen N, Schauerte P, Lichtenberg A, Balzer J, Rassaf T, Perings S, Kelm M, Shin DI, Meyer C. Improvement of left ventricular function under cardiac resynchronization therapy goes along with a reduced incidence of ventricular arrhythmia. PLoS One. 2012:e48926. [pmid: 23152822].
Sullivan RM, Murillo J, Gerritse B, Chung E, Orlov MV, Stegemann B, Fedewa M, Peterson BJ, Sun JP, Olshansky B. Do baseline diastolic echocardiographic parameters predict outcome after resynchronization therapy? Results from the PROSPECT trial. Pacing Clin Electrophysiol. 2013:214-220. [pmid: 23121136].
Aly MF, Kleijn SA, de Boer K, Abd El-Hady YA, Sorour KA, Kandil HI, van Rossum AC, Kamp O. Comparison of three-dimensional echocardiographic software packages for assessment of left ventricular mechanical dyssynchrony and prediction of response to cardiac resynchronization therapy. Eur Heart J Cardiovasc Imaging. 2013:700-710. [pmid: 23111693].
Barbhaiya C, Po JR, Hanon S, Schweitzer P. Tpeak - Tend and Tpeak - Tend/QT ratio as markers of ventricular arrhythmia risk in cardiac resynchronization therapy patients. Pacing Clin Electrophysiol. 2013:103-108. [pmid: 23106253].
Celikyurt U, Agacdiken A, Sahin T, Al N, Kozdag G, Vural A, Ural D. Number of leads with fragmented QRS predicts response to cardiac resynchronization therapy. Clin Cardiol. 2013:36-39. [pmid: 23081693].
Hitz L, Kuhne MS, Sticherling C, Osswald S, Schaer BA. Adjustments of heart failure medication after implantation of a cardiac resynchronization therapy defibrillator. Minerva Med. 2012:361-367. [pmid: 23042371].
Arias MA, Pachon M, Puchol A, Jimenez-Lopez J, Rodriguez-Padial L. Acute and mid-term outcomes of transvenous implant of a new left ventricular quadripolar lead versus bipolar leads for cardiac resynchronization therapy: results from a single-center prospective database. Cardiol J. 2012:470-478. [pmid: 23042310].
Guha K, Mantziari L, Sharma R, McDonagh TA, Gibson D, Duncan AM. A reduction in total isovolumic time with cardiac resynchronisation therapy is a predictor of clinical outcomes. Int J Cardiol. 2013:382-387. [pmid: 23041011].
Whellan DJ, Sarkar S, Koehler J, Small RS, Boyle A, Warman EN, Abraham WT. Development of a method to risk stratify patients with heart failure for 30-day readmission using implantable device diagnostics. Am J Cardiol. 2013:79-84. [pmid: 23040596].
Kamioka M, Suzuki H, Yamada S, Kamiyama Y, Saitoh S, Takeishi Y. High sensitivity C-reactive protein predicts nonresponders and cardiac deaths in severe heart failure patients after CRT implantation. Int Heart J. 2012:306-312. [pmid: 23038092].
Leyva F, Taylor RJ, Foley PW, Umar F, Mulligan LJ, Patel K, Stegemann B, Haddad T, Smith RE, Prasad SK. Left ventricular midwall fibrosis as a predictor of mortality and morbidity after cardiac resynchronization therapy in patients with nonischemic cardiomyopathy. J Am Coll Cardiol. 2012:1659-1667. [pmid: 23021326].
Arao K, Fujiwara T, Sakakura K, Wada H, Sugawara Y, Suga C, Ako J, Ishikawa SE, Momomura S. Hyponatremia as a predictor for worsening heart failure in patients receiving cardiac resynchronization therapy. Circ J. 2013:116-122. [pmid: 23018767].
Schau T, Koglek W, Brandl J, Seifert M, Meyhofer J, Neuss M, Grimm G, Bitschnau R, Butter C. Baseline vectorcardiography as a predictor of invasively determined acute hemodynamic response to cardiac resynchronization therapy. Clin Res Cardiol. 2013:129-138. [pmid: 23001244].
Kusiak A, Wilinski J, Wojciechowska W, Jastrzebski M, Sondej T, Bacior B, Kloch-Badelek M, Czarnecka D. Effects of biventricular pacing on right ventricular function assessed by standard echocardiography. Kardiol Pol. 2012:883-888. [pmid: 22992994].
Imanishi J, Tanaka H, Matsumoto K, Tatsumi K, Miyoshi T, Hiraishi M, Kaneko A, Ryo K, Fukuda Y, Yoshida A, Yokoyama M, Kawai H, Hirata K. Utility of combined assessment of baseline dyssynchrony and its acute improvement to predict long-term outcomes after cardiac resynchronization therapy. Am J Cardiol. 2012:1814-1819. [pmid: 22981265].
Kandala J, Upadhyay GA, Altman RK, Bose A, Heist EK, Mela T, Singh JP. Electrical delay in apically positioned left ventricular leads and clinical outcome after cardiac resynchronization therapy. J Cardiovasc Electrophysiol. 2013:182-187. [pmid: 22966852].
Abu Sham'a R, Buber J, Grupper A, Nof E, Kuperstein R, Luria D, Feinberg MS, Eldar M, Glikson M. Effects of tricuspid valve regurgitation on clinical and echocardiographic outcome in patients with cardiac resynchronization therapy. Europace. 2013:266-272. [pmid: 22952208].
Celikyurt U, Agacdiken A, Sahin T, Al N, Vural A, Ural D. Relationship between fragmented QRS and response to cardiac resynchronization therapy. J Interv Card Electrophysiol. 2012:337-342. discussion 342. [pmid: 22926204].
Kyriacou A, Whinnett ZI, Sen S, Pabari PA, Wright I, Cornelussen R, Lefroy D, Davies DW, Peters NS, Kanagaratnam P, Mayet J, Hughes AD, Francis DP, Davies JE. Improvement in coronary blood flow velocity with acute biventricular pacing is predominantly due to an increase in a diastolic backward-travelling decompression (suction) wave. Circulation. 2012:1334-1344. [pmid: 22855569].
Bogaard MD, Hesselink T, Meine M, Loh P, Hauer RN, Cramer MJ, Doevendans PA, Tuinenburg AE. The ECG in cardiac resynchronization therapy: influence of left and right ventricular preactivation and relation to acute response. J Cardiovasc Electrophysiol. 2012:1237-1245. [pmid: 22734629].
Miyata M, Yoshihisa A, Suzuki S, Yamada S, Kamioka M, Kamiyama Y, Yamaki T, Sugimoto K, Kunii H, Nakazato K, Suzuki H, Saitoh S, Takeishi Y. Adaptive servo ventilation improves Cheyne-Stokes respiration, cardiac function, and prognosis in chronic heart failure patients with cardiac resynchronization therapy. J Cardiol. 2012:222-227. [pmid: 22727431].
Rodriguez DJ, Afzal A, Evonich R, Haines DE. The prevalence of methicillin resistant organisms among pacemaker and defibrillator implant recipients. Am J Cardiovasc Dis. 2012:116-122. [pmid: 22720201].
Valzania C, Gadler F, Boriani G, Eriksson MJ. Changes in global longitudinal strain during rest and exercise in patients treated with cardiac resynchronization therapy. Clin Physiol Funct Imaging. 2012:310-316. [pmid: 22681609].
Momomura S, Tsutsui H, Sugawara Y, Ito M, Mitsuhashi T, Fukamizu S, Noro M, Matsumoto N, Tejima T, Sugi K. Clinical efficacy of cardiac resynchronization therapy with an implantable defibrillator in a Japanese population: results of the MIRACLE-ICD outcome measured in Japanese indication (MOMIJI) study. Circ J. 2012:1911-1919. [pmid: 22664486].
Himmel F, Reppel M, Mortensen K, Schunkert H, Bode F. A strategy to achieve CRT response in permanent atrial fibrillation without obligatory atrioventricular node ablation. Pacing Clin Electrophysiol. 2012:943-947. [pmid: 22650352].
Malagoli A, Rossi L, Franchi F, Piepoli MF, Malavasi V, Casali E, Modena MG, Villani GQ. Effect of cardiac resynchronization therapy on left atrial reverse remodeling: role of echocardiographic AV delay optimization. Int J Cardiol. 2013:1456-1460. [pmid: 22560916].
Tomczak CR, Paterson I, Haykowsky MJ, Lawrance R, Martellotto A, Pantano A, Gulamhusein S, Haennel RG. Cardiac resynchronization therapy modulation of exercise left ventricular function and pulmonary O(2) uptake in heart failure. Am J Physiol Heart Circ Physiol. 2012:H2635-H2645. [pmid: 22523249].
Smith T, Levy WC, Schaer BA, Balk AH, Sticherling C, Jordaens L, Theuns DA. Performance of the Seattle Heart Failure Model in implantable defibrillator patients treated with cardiac resynchronization therapy. Am J Cardiol. 2012:398-402. [pmid: 22516524].
Shahrzad S, Soleiman NK, Taban S, Alizadeh A, Aslani A, Tavoosi A, Emkanjoo Z. The effect of left ventricular (LV) remodeling on ventricular arrhythmia in cardiac resynchronization therapy (CRT-D) patients (antiarrhythmic effect of CRT). Pacing Clin Electrophysiol. 2012:592-597. [pmid: 22429264].
Zizek D, Cvijic M, Tasic J, Jan M, Frljak S, Zupan I. Effect of cardiac resynchronization therapy on beat-to-beat T-wave amplitude variability. Europace. 2012:1646-1652. [pmid: 22423254].
Sweeney MO, Sakaguchi S, Simons G, Machado C, Connett JE, Yang F. Response to the Center for Medicare &amp; Medicaid Services coverage with evidence development request for primary prevention implantable cardioverter-defibrillators: data from the OMNI study. Heart Rhythm. 2012:1058-1066. [pmid: 22387371].
Stabile G, D'Agostino C, Gallo P, Marrazzo N, Iuliano A, De Simone A, Turco P, Palella M, Donnici G, Ciardiello C, Napolitano G, Solimene F. Appropriate therapies predict long-term mortality in primary and secondary prevention of sudden cardiac death. J Cardiovasc Med (Hagerstown). 2013:110-113. [pmid: 22367567].
Hotta VT, Martinelli Filho M, Mathias W Jr, Vieira ML. New equation for prediction of reverse remodeling after cardiac resynchronization therapy. Echocardiography. 2012:678-687. [pmid: 22348339].
Zhang Q, Chan YS, Liang YJ, Fang F, Lam YY, Chan CP, Lee AP, Chan KC, Wu EB, Yu CM. Comparison of left ventricular reverse remodeling induced by cardiac contractility modulation and cardiac resynchronization therapy in heart failure patients with different QRS durations. Int J Cardiol. 2013:889-893. [pmid: 22330007].
Bank AJ, Burns KV, Gage RM, Vatterott DB, Adler SW, Sajady M, Rohde D, Parah JS, Anand I, Yong P, Seth M, Kubo SH. Cardiac resynchronization therapy in the real world: comparison with the COMPANION study. J Card Fail. 2012:153-158. [pmid: 22300784].
Biasucci LM, Bellocci F, Landolina M, Rordorf R, Vado A, Menardi E, Giubilato G, Orazi S, Sassara M, Castro A, Massa R, Kheir A, Zaccone G, Klersy C, Accardi F, Crea F. Risk stratification of ischaemic patients with implantable cardioverter defibrillators by C-reactive protein and a multi-markers strategy: results of the CAMI-GUIDE study. Eur Heart J. 2012:1344-1350. [pmid: 22285581].
Pugliese M, Minardi G, Vitali A, Natale E, De Girolamo P, Zampi G, Leggio M, Chiarelli A, Pappalardo A, Avella A, Laurenzi F, Fera MS. Influence of myocardial viability on responsiveness to cardiac resynchronization in ischemic dilated cardiomyopathy: a prospective observational cohort study. Anadolu Kardiyol Derg. 2012:132-141. [pmid: 22281793].
Donahue T, Niazi I, Leon A, Stucky M, Herrmann K. Acute and chronic response to CRT in narrow QRS patients. J Cardiovasc Transl Res. 2012:232-241. [pmid: 22207279].
Limongelli G, Roselli T, Pacileo G, Calabro P, Maddaloni V, Masarone D, Riegler L, Gravino R, Scarafile R, Salerno G, Miele T, D'Andrea A, Santangelo L, Romano M, Di Salvo G, Russo MG, Calabro R. Effect of cardiac resynchronization therapy on cardiotrophin-1 circulating levels in patients with heart failure. Intern Emerg Med. 2014:43-50. [pmid: 22179744].
Morales MA, Startari U, Rossi G, Panchetti L, Rossi A, Piacenti M. Reverse left ventricular remodeling is more likely in non ischemic cardiomyopathy patients upgraded to biventricular stimulation after chronic right ventricular pacing. Cardiovasc Ultrasound. 2011:41. [pmid: 22177469].
Perrin MJ, Green MS, Redpath CJ, Nery PB, Keren A, Beanlands RS, Birnie DH. Greater response to cardiac resynchronization therapy in patients with true complete left bundle branch block: a PREDICT substudy. Europace. 2012:690-695. [pmid: 22170897].
Epstein AJ, Polsky D, Yang F, Yang L, Groeneveld PW. Geographic variation in implantable cardioverter-defibrillator use and heart failure survival. Med Care. 2012:10-17. [pmid: 22167063].
Luedorff G, Grove R, Kowalski M, Wolff E, Thale J, Kranig W. Impact of chronic atrial fibrillation in patients with severe heart failure and indication for CRT: data of two registries with 711 patients (1999-2006 and 2007-6/2008). Herzschrittmacherther Elektrophysiol. 2011:226-232. [pmid: 22160274].
Boriani G, Gasparini M, Landolina M, Lunati M, Biffi M, Santini M, Padeletti L, Molon G, Botto G, de Santo T, Valsecchi S. Impact of mitral regurgitation on the outcome of patients treated with CRT-D: data from the InSync ICD Italian Registry. Pacing Clin Electrophysiol. 2012:146-154. [pmid: 22132940].
Aksoy H, Okutucu S, Aytemir K, Kaya EB, Evranos B, Kabakci G, Tokgozoglu L, Ozkutlu H, Oto A. Baseline aortic pre-ejection interval predicts reverse remodeling and clinical improvement after cardiac resynchronization therapy. Cardiol J. 2011:639-647. [pmid: 22113751].
Lopez-Andres N, Rossignol P, Iraqi W, Fay R, Nuee J, Ghio S, Cleland JG, Zannad F, Lacolley P. Association of galectin-3 and fibrosis markers with long-term cardiovascular outcomes in patients with heart failure, left ventricular dysfunction, and dyssynchrony: insights from the CARE-HF (Cardiac Resynchronization in Heart Failure) trial. Eur J Heart Fail. 2012:74-81. [pmid: 22089058].
Kobe J, Dechering DG, Rath B, Reinke F, Monnig G, Wasmer K, Eckardt L. Prospective evaluation of electrocardiographic parameters in cardiac resynchronization therapy: detecting nonresponders by left ventricular pacing. Heart Rhythm. 2012:499-504. [pmid: 22079557].
Verhaert D, Popovic ZB, De S, Puntawangkoon C, Wolski K, Wilkoff BL, Starling RC, Tang WH, Thomas JD, Griffin BP, Grimm RA. Impact of mitral regurgitation on reverse remodeling and outcome in patients undergoing cardiac resynchronization therapy. Circ Cardiovasc Imaging. 2012:21-26. [pmid: 22047983].
Alpendurada F, Guha K, Sharma R, Ismail TF, Clifford A, Banya W, Mohiaddin RH, Pennell DJ, Cowie MR, McDonagh T, Prasad SK. Right ventricular dysfunction is a predictor of non-response and clinical outcome following cardiac resynchronization therapy. J Cardiovasc Magn Reson. 2011:68. [pmid: 22040270].
Ciampi Q, Pratali L, Citro R, Villari B, Picano E, Sicari R. Additive value of severe diastolic dysfunction and contractile reserve in the identification of responders to cardiac resynchronization therapy. Eur J Heart Fail. 2011:1323-1330. [pmid: 22037388].
Grosu A, Senni M, Iacovoni A, Gori M, Cantu F, Bisetti S, De Santo T, De Luca A, Gavazzi A. CArdiac resynchronization in combination with beta blocker treatment in advanced chronic heart failure (CARIBE-HF): the results of the CARIBE-HF study. Acta Cardiol. 2011:573-580. [pmid: 22032050].
Szulik M, Stabryla-Deska J, Boidol J, Lenarczyk R, Kalarus Z, Kukulski T. Echocardiography-based qualification and response assessment to cardiac resynchronisation therapy in patients with chronic heart failure. The matrix metalloproteinase-9 substudy. Kardiol Pol. 2011:1043-1051. [pmid: 22006606].
Carluccio E, Biagioli P, Alunni G, Murrone A, Pantano P, Biscottini E, Zuchi C, Zingarini G, Cavallini C, Ambrosio G. Presence of extensive LV remodeling limits the benefits of CRT in patients with intraventricular dyssynchrony. JACC Cardiovasc Imaging. 2011:1067-1076. [pmid: 21999865].
Faber L, Vlachojannis M, Oldenburg O, Hering D, Bogunovic N, Horstkotte D, Lamp B. Long-term follow-up of cardiac resynchronization therapy: mechanical resynchronization and reverse left ventricular remodeling are predictive for long-term transplant-free survival. Int J Cardiovasc Imaging. 2012:1341-1350. [pmid: 21964638].
Blaschke F, Knaus T, Celebi O, Krebs A, Nitardy A, Habedank D, Dietz R, Stockburger M. Ventricular tachycardia or ventricular fibrillation occurs less often in patients with left bundle branch block and combined resynchronization and defibrillators than in patients with narrow QRS and conventional defibrillators. Europace. 2012:224-229. [pmid: 21946820].
Tereshchenko LG, Henrikson CA, Berger RD. Strong coherence between heart rate variability and intracardiac repolarization lability during biventricular pacing is associated with reverse electrical remodeling of the native conduction and improved outcome. J Electrocardiol. 2011:713-717. [pmid: 21944164].
Tournoux F, Singh JP, Chan RC, Chen-Tournoux A, McCarty D, Manzke R, Ruskin JN, Semigran M, Heist EK, Moore S, Picard MH, Weyman AE. Absence of left ventricular apical rocking and atrial-ventricular dyssynchrony predicts non-response to cardiac resynchronization therapy. Eur Heart J Cardiovasc Imaging. 2012:86-94. [pmid: 21921079].
Theodorakis G, Katsikis A, Livanis E, Kostopoulou A, Adamopoulos S, Tsiapras D, Voudris V. Long term effects of cardiac resynchronization therapy in non-ambulatory NYHA IV heart failure patients. Pacing Clin Electrophysiol. 2011:1553-1560. [pmid: 21913946].
Celikyurt U, Vural A, Sahin T, Kilic T, Agacdiken A, Ural D. Relationship between left ventricular dyssynchrony and reverse remodeling after cardiac resynchronization therapy. Clin Cardiol. 2011:645-648. [pmid: 21913208].
Prochnau D, Kuehnert H, Figulla HR, Surber R. QRS duration and QTc interval are predictors of risk for ventricular arrhythmias during cardiac resynchronization therapy. Acta Cardiol. 2011:415-420. [pmid: 21894795].
Rickard J, Bassiouny M, Cronin EM, Martin DO, Varma N, Niebauer MJ, Tchou PJ, Tang WH, Wilkoff BL. Predictors of response to cardiac resynchronization therapy in patients with a non-left bundle branch block morphology. Am J Cardiol. 2011:1576-1580. [pmid: 21890086].
Celikyurt U, Agacdiken A, Geyik B, Kozdag G, Vural A, Ural D. Effect of cardiac resynchronization therapy on thyroid function. Clin Cardiol. 2011:703-705. [pmid: 21887693].
Shanks M, Antoni ML, Hoke U, Bertini M, Ng AC, Auger D, Marsan NA, van Erven L, Holman ER, Schalij MJ, Bax JJ, Delgado V. The effect of cardiac resynchronization therapy on left ventricular diastolic function assessed with speckle-tracking echocardiography. Eur J Heart Fail. 2011:1133-1139. [pmid: 21873339].
Nakamura K, Takami M, Shimabukuro M, Maesato A, Chinen I, Ishigaki S, Higa S, Keida T, Masuzaki H. Effective prediction of response to cardiac resynchronization therapy using a novel program of gated myocardial perfusion single photon emission computed tomography. Europace. 2011:1731-1737. [pmid: 21873328].
Matsumoto K, Tanaka H, Okajima K, Hayashi T, Kajiya T, Kawai H, Hirata K. Relation between left ventricular morphology and reduction in functional mitral regurgitation by cardiac resynchronization therapy in patients with idiopathic dilated cardiomyopathy. Am J Cardiol. 2011:1327-1334. [pmid: 21864818].
Albertsen AE, Mortensen PT, Jensen HK, Poulsen SH, Egeblad H, Nielsen JC. Adverse effect of right ventricular pacing prevented by biventricular pacing during long-term follow-up: a randomized comparison. Eur J Echocardiogr. 2011:767-772. [pmid: 21857020].
Lim P, Donal E, Lafitte S, Derumeaux G, Habib G, Reant P, Thivolet S, Lellouche N, Grimm RA, Gueret P. Multicentre study using strain delay index for predicting response to cardiac resynchronization therapy (MUSIC study). Eur J Heart Fail. 2011:984-991. [pmid: 21810831].
Verna E, Ghiringhelli S, Scotti S, Caravati F. Evaluation of baseline contractile reserve vs dyssynchrony as a predictor of functional improvement and long term outcome after resynchronization pacing therapy: a radionuclide stress study. J Nucl Cardiol. 2012:53-62. [pmid: 21769704].
Ronn F, Kesek M, Karp K, Henein M, Jensen SM. Right ventricular lead positioning does not influence the benefits of cardiac resynchronization therapy in patients with heart failure and atrial fibrillation. Europace. 2011:1747-1752. [pmid: 21712261].
Shen X, Nair CK, Aronow WS, Hee T, Esterbrooks DJ. Effect of carvedilol versus metoprolol CR/XL on mortality in patients with heart failure treated with cardiac resynchronization therapy: a COX multivariate regression analysis. Am J Ther. 2013:247-353. [pmid: 21642836].
Aarones M, Gullestad L, Aakhus S, Ueland T, Skaardal R, Aass H, Wergeland R, Smith HJ, Aukrust P, Kongsgaard E. Prognostic value of cardiac troponin T in patients with moderate to severe heart failure scheduled for cardiac resynchronization therapy. Am Heart J. 2011:1031-1037. [pmid: 21641347].
Lousinha A, Oliveira MM, Feliciano J, Galrinho A, Branco LM, Cunha PS, Hamad H, Ramos R, Abreu J, Leal A, Santos S, Soares R, da Silva MN, Ferreira RC. Benefits of cardiac resynchronization therapy in &quot;very dilated cardiomyopathy&quot;. Rev Port Cardiol. 2011:283-294. [pmid: 21638987].
Vural A, Agacdiken A, Celikyurt U, Culha M, Kahraman G, Kozdag G, Ural D. Effect of cardiac resynchronization therapy on libido and erectile dysfunction. Clin Cardiol. 2011:437-441. [pmid: 21638287].
Pouleur AC, Knappe D, Shah AM, Uno H, Bourgoun M, Foster E, McNitt S, Hall WJ, Zareba W, Goldenberg I, Moss AJ, Pfeffer MA, Solomon SD. Relationship between improvement in left ventricular dyssynchrony and contractile function and clinical outcome with cardiac resynchronization therapy: the MADIT-CRT trial. Eur Heart J. 2011:1720-1729. [pmid: 21609974].
van Gelder IC, Phan HM, Wilkoff BL, Brown ML, Rogers T, Peterson BJ, Birgersdotter-Green UM. Prognostic significance of atrial arrhythmias in a primary prevention ICD population. Pacing Clin Electrophysiol. 2011:1070-1079. [pmid: 21605131].
Mischke K, Knackstedt C, Fache K, Reith S, Rana O, Saygili E, Gemein C, Becker M, Marx N, Schauerte P. Electrical remodelling in cardiac resynchronization therapy: decrease in intrinsic QRS duration. Acta Cardiol. 2011:175-180. [pmid: 21591575].
Scheffer MG, van Dessel PF, van Gelder BM, Sutherland GR, van Hemel NM. Peak longitudinal strain delay is superior to TDI in the selection of patients for resynchronisation therapy. Neth Heart J. 2010:574-582.
Boriani G, Gasparini M, Landolina M, Lunati M, Proclemer A, Lonardi G, Iacopino S, Rahue W, Biffi M, DiStefano P, Grammatico A, Santini M. Incidence and clinical relevance of uncontrolled ventricular rate during atrial fibrillation in heart failure patients treated with cardiac resynchronization therapy. Eur J Heart Fail. 2011:868-876. [pmid: 21558331].
Dendy KF, Powell BD, Cha YM, Espinosa RE, Friedman PA, Rea RF, Hayes DL, Redfield MM, Asirvatham SJ. Anodal stimulation: an underrecognized cause of nonresponders to cardiac resynchronization therapy. Indian Pacing Electrophysiol J. 2011:64-72. [pmid: 21556155].
Altman RK, McCarty D, Chen-Tournoux AA, Tournoux FB, Riedl L, Orencole M, Park MY, Picard MH, Singh JP. Usefulness of low-dose dobutamine echocardiography to predict response and outcome in patients undergoing cardiac resynchronization therapy. Am J Cardiol. 2011:252-257. [pmid: 21550579].
Vitarelli A, Franciosa P, Nguyen BL, Capotosto L, Ciccaglioni A, Conde Y, Iorio G, De Curtis G, Caranci F, Vitarelli M, Lucchetti P, Dettori O, De Cicco V. Additive value of right ventricular dyssynchrony indexes in predicting the success of cardiac resynchronization therapy: a speckle-tracking imaging study. J Card Fail. 2011:392-402. [pmid: 21549296].
Rickard J, Zardkoohi O, Popovic Z, Verhaert D, Sraow D, Baranowski B, Martin DO, Grimm RA, Chung MK, Tchou P, Lindsay BA, Wilkoff BL. QRS fragmentation is not associated with poor response to cardiac resynchronization therapy. Ann Noninvasive Electrocardiol. 2011:165-171. [pmid: 21496167].
Becker M, Zwicker C, Kaminski M, Napp A, Altiok E, Ocklenburg C, Friedman Z, Adam D, Schauerte P, Marx N, Hoffmann R. Dependency of cardiac resynchronization therapy on myocardial viability at the LV lead position. JACC Cardiovasc Imaging. 2011:366-374. [pmid: 21492811].
Muellerleile K, Baholli L, Groth M, Koopmann K, Barmeyer A, Gosau N, Ventura R, Rostock T, Koester R, Adam G, Willems S, Lund G. Quantification of mechanical ventricular dyssynchrony: direct comparison of velocity-encoded and cine magnetic resonance imaging. Rofo. 2011:554-560. [pmid: 21487982].
Wei S, Loyo-Berrios NI, Haigney MC, Cheng H, Pinnow EE, Mitchell KR, Beachy JH, Woodward AM, Wang Y, Curtis JP, Marinac-Dabic D. Elevated B-type natriuretic peptide is associated with increased in-hospital mortality or cardiac arrest in patients undergoing implantable cardioverter-defibrillator implantation. Circ Cardiovasc Qual Outcomes. 2011:346-354. [pmid: 21487093].
Lellouche N, De Diego C, Boyle NG, Wiener I, Akopyan G, Child JS, Shivkumar K. Relationship between mechanical and electrical remodelling in patients with cardiac resynchronization implanted defibrillators. Europace. 2011:1180-1187. [pmid: 21486911].
Kalogeropoulos A, Savoye LP, Georgiopoulou V, Raj L, Lloyd MS, Chiladakis J, Lerakis S, Alexopoulos D, Butler J. Long-term response of the left ventricle to cardiac resynchronization therapy: insights from standard and strain echocardiography. Congest Heart Fail. 2011:71-79. [pmid: 21449995].
Martin DT, McNitt S, Nesto RW, Rutter MK, Moss AJ. Cardiac resynchronization therapy reduces the risk of cardiac events in patients with diabetes enrolled in the multicenter automatic defibrillator implantation trial with cardiac resynchronization therapy (MADIT-CRT). Circ Heart Fail. 2011:332-338. [pmid: 21350054].
Adelstein E, Schwartzman D, Gorcsan J 3rd, Saba S. Predicting hyperresponse among pacemaker-dependent nonischemic cardiomyopathy patients upgraded to cardiac resynchronization. J Cardiovasc Electrophysiol. 2011:905-911. [pmid: 21332868].
Kirubakaran S, Ladwiniec A, Arujuna A, Ginks M, McPhail M, Bostock J, Carr-White G, Rinaldi CA. Male gender and chronic obstructive pulmonary disease predict a poor clinical response in patients undergoing cardiac resynchronisation therapy. Int J Clin Pract. 2011:281-288. [pmid: 21314865].
Scheffer MG, van Dessel PF, van Gelder BM, Sutherland GR, van Hemel NM. Peak longitudinal strain delay is superior to TDI in the selection of patients for resynchronisation therapy. Neth Heart J. 2010:574-582.
Rickard J, Popovic Z, Verhaert D, Sraow D, Baranowski B, Martin DO, Lindsay BD, Varma N, Tchou P, Grimm RA, Wilkoff BL, Chung MK. The QRS narrowing index predicts reverse left ventricular remodeling following cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2011:604-611. [pmid: 21276023].
Zaca V, Baiocchi C, Gaddi R, Gentilini R, Lunghetti S, Padeletti M, Pagliaro A, Furiozzi F, Mondillo S, Favilli R. Influence of aetiology on long-term effects of resynchronization on cardiac structure and function in patients treated with beta-blockers. J Cardiovasc Med (Hagerstown). 2011:227-233. [pmid: 21252694].
Santini M, Gasparini M, Landolina M, Lunati M, Proclemer A, Padeletti L, Catanzariti D, Molon G, Botto GL, La Rocca L, Grammatico A, Boriani G. Device-detected atrial tachyarrhythmias predict adverse outcome in real-world patients with implantable biventricular defibrillators. J Am Coll Cardiol. 2011:167-172. [pmid: 21211688].
Gold MR, Linde C, Abraham WT, Gardiwal A, Daubert JC. The impact of cardiac resynchronization therapy on the incidence of ventricular arrhythmias in mild heart failure. Heart Rhythm. 2011:679-684. [pmid: 21185401].
Bertini M, Ziacchi M, Biffi M, Biagini E, Rocchi G, Martignani C, Ferlito M, Pasquale F, Cervi E, Branzi A, Rapezzi C, Boriani G. Effects of cardiac resynchronisation therapy on dilated cardiomyopathy with isolated ventricular non-compaction. Heart. 2011:295-300. [pmid: 21163889].
Clements IP, Christenson S, Hodge DO, Mullan BP, Redfield MM, Hayes DL. Symptom improvement after upgrade from right ventricular apical to biventricular pacing: Role of right and left ventricular volumes assessed with single-photon emission computed tomographic equilibrium radionuclide angiocardiography. J Nucl Cardiol. 2011:43-51. [pmid: 21128041].
Chaudhry FA, Shah A, Bangalore S, DeRose J, Steinberg JS. Inotropic contractile reserve and response to cardiac resynchronization therapy in patients with markedly remodeled left ventricle. J Am Soc Echocardiogr. 2011:91-97. [pmid: 21126856].
Schaer B, Theuns DA, Sticherling C, Szili-Torok T, Osswald S, Jordaens L. Effect of implantable cardioverter-defibrillator on left ventricular ejection fraction in patients with idiopathic dilated cardiomyopathy. Am J Cardiol. 2010:1640-1645. [pmid: 21094367].
Tereshchenko LG, Henrikson CA, Stempniewicz P, Han L, Berger RD. Antiarrhythmic effect of reverse electrical remodeling associated with cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2011:357-364. [pmid: 21091740].
Linde C, Abraham WT, Gold MR, Daubert C. Cardiac resynchronization therapy in asymptomatic or mildly symptomatic heart failure patients in relation to etiology: results from the REVERSE (REsynchronization reVErses Remodeling in Systolic Left vEntricular Dysfunction) study. J Am Coll Cardiol. 2010:1826-1831. [pmid: 21087711].
Lin G, Gersh BJ, Greene EL, Redfield MM, Hayes DL, Brady PA. Renal function and mortality following cardiac resynchronization therapy. Eur Heart J. 2011:184-190. [pmid: 21068051].
Foley PW, Chalil S, Khadjooi K, Irwin N, Smith RE, Leyva F. Left ventricular reverse remodelling, long-term clinical outcome, and mode of death after cardiac resynchronization therapy. Eur J Heart Fail. 2011:43-51. [pmid: 21051462].
Gorcsan J 3rd, Oyenuga O, Habib PJ, Tanaka H, Adelstein EC, Hara H, McNamara DM, Saba S. Relationship of echocardiographic dyssynchrony to long-term survival after cardiac resynchronization therapy. Circulation. 2010:1910-1918. [pmid: 20975000].
Castellant P, Orhan E, Bertault-Valls V, Fatemi M, Etienne Y, Blanc JJ. Is &quot;hyper response&quot to cardiac resynchronization therapy in patients with nonischemic cardiomyopathy a recovery, a remission, or a control?. Ann Noninvasive Electrocardiol. 2010:321-327. [pmid: 20946554].
Aksoy H, Okutucu S, Aytemir K, Kaya EB, Tulumen E, Evranos B, Fatihoglu SG, Kabakci G, Tokgozoglu L, Ozkutlu H, Oto A. Improvement in right ventricular systolic function after cardiac resynchronization therapy correlates with left ventricular reverse remodeling. Pacing Clin Electrophysiol. 2011:200-207. [pmid: 20883514].
Bank AJ, Kaufman CL, Burns KV, Parah JS, Johnson L, Kelly AS, Shroff SG, Kaiser DR. Intramural dyssynchrony and response to cardiac resynchronization therapy in patients with and without previous right ventricular pacing. Eur J Heart Fail. 2010:1317-1324. [pmid: 20864481].
Bertini M, Delgado V, Nucifora G, Marsan NA, Ng AC, Shanks M, Van Bommel RJ, Borleffs CJ, Ewe SH, Boriani G, Biffi M, Schalij MJ, Bax JJ. Effect of cardiac resynchronization therapy on subendo- and subepicardial left ventricular twist mechanics and relation to favorable outcome. Am J Cardiol. 2010:682-687. [pmid: 20723646].
Miyazaki C, Redfield MM, Powell BD, Lin GM, Herges RM, Hodge DO, Olson LJ, Hayes DL, Espinosa RE, Rea RF, Bruce CJ, Nelson SM, Miller FA, Oh JK. Dyssynchrony indices to predict response to cardiac resynchronization therapy: a comprehensive prospective single-center study. Circ Heart Fail. 2010:565-573. [pmid: 20647479].
Bisch L, Da Costa A, Dauphinot V, Romeyer-Bouchard C, Khris L, M'baye A, Isaaz K. Predictive factors of difficult implantation procedure in cardiac resynchronization therapy. Europace. 2010:1141-1148. [pmid: 20573673].
Voigt A, Shalaby A, Adelstein E, Saba S. Beta-blocker utilization and outcomes in patients receiving cardiac resynchronization therapy. Clin Cardiol. 2010:E1-E5. [pmid: 20549778].
Castel MA, Magnani S, Mont L, Roig E, Tamborero D, Mendez-Zurita F, Femenia JF, Tolosana JM, Perez-Villa F, Brugada J. Survival in New York Heart Association class IV heart failure patients treated with cardiac resynchronization therapy compared with patients on optimal pharmacological treatment. Europace. 2010:1136-1140. [pmid: 20543199].
Lipoldova J, Ozabalova E, Meluzin J, Novak M, Vitovec J. Usefulness of left ventricle dyssynchrony assessment before cardiac resynchronization implantation. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. 2010:39-46. [pmid: 20445710].
Jaussaud J, Blanc P, Derval N, Bordachar P, Courregelongue M, Roudaut R, Douard H. Ventilatory response and peak circulatory power: new functional markers of response after cardiac resynchronization therapy. Arch Cardiovasc Dis. 2010:184-191. [pmid: 20417450].
Reant P, Zaroui A, Donal E, Mignot A, Bordachar P, Deplagne A, Solnon A, Ritter P, Daubert JC, Clementy J, Leclercq C, Roudaut R, Habib G, Lafitte S. Identification and characterization of super-responders after cardiac resynchronization therapy. Am J Cardiol. 2010:1327-1335. [pmid: 20403487].
Frohlich G, Steffel J, Hurlimann D, Enseleit F, Luscher TF, Ruschitzka F, Abraham WT, Holzmeister J. Upgrading to resynchronization therapy after chronic right ventricular pacing improves left ventricular remodelling. Eur Heart J. 2010:1477-1485. [pmid: 20233792].
Chandra R, Zolty R, Palma E. A left hemiblock improves cardiac resynchronization therapy outcomes in patients with a right bundle branch block. Clin Cardiol. 2010:89-93. [pmid: 20186989].
Vidal B, Delgado V, Mont L, Poyatos S, Silva E, Angeles Castel M, Tolosana JM, Berruezo A, Brugada J, Sitges M. Decreased likelihood of response to cardiac resynchronization in patients with severe heart failure. Eur J Heart Fail. 2010:283-287. [pmid: 20156941].
Soliman OI, Theuns DA, van Dalen BM, Vletter WB, Nemes A, Jordaens LJ, Balk AH, Ten Cate FJ, Geleijnse ML. Prediction of appropriate defibrillator therapy in heart failure patients treated with cardiac resynchronization therapy. Am J Cardiol. 2010:105-111. [pmid: 20102900].
Sweeney MO, van Bommel RJ, Schalij MJ, Borleffs CJ, Hellkamp AS, Bax JJ. Analysis of ventricular activation using surface electrocardiography to predict left ventricular reverse volumetric remodeling during cardiac resynchronization therapy. Circulation. 2010:626-634. [pmid: 20100970].
van Geldorp IE, Vernooy K, Delhaas T, Prins MH, Crijns HJ, Prinzen FW, Dijkman B. Beneficial effects of biventricular pacing in chronically right ventricular paced patients with mild cardiomyopathy. Europace. 2010:223-229. [pmid: 19966323].
Burri H, Domenichini G, Sunthorn H, Fleury E, Stettler C, Foulkes I, Shah D. Right ventricular systolic function and cardiac resynchronization therapy. Europace. 2010:389-394. [pmid: 19966321].
Desai H, Aronow WS, Ahn C, Tsai FS, Lai HM, Gandhi K, Amin H, Frishman WH, Kalapatapu K, Cohen M, Sorbera C. Incidence of appropriate cardioverter-defibrillator shocks and mortality in patients with heart failure treated with combined cardiac resynchronization plus implantable cardioverter-defibrillator therapy versus implantable cardioverter-defibrillator therapy. J Cardiovasc Pharmacol Ther. 2010:37-40. [pmid: 19966176].
Tarquini R, Guerra CT, Porciani MC, Michelucci A, Padeletti M, Ricciardi G, Chiostri M, Jelic S, Padeletti L. Effects of cardiac resynchronization therapy on systemic inflammation and neurohormonal pathways in heart failure. Cardiol J. 2009:545-552. [pmid: 19950091].
Cabrera-Bueno F, Molina-Mora MJ, Alzueta J, Pena-Hernandez J, Jimenez-Navarro M, Fernandez-Pastor J, Barrera A, de Teresa E. Persistence of secondary mitral regurgitation and response to cardiac resynchronization therapy. Eur J Echocardiogr. 2010:131-137. [pmid: 19939817].
Sassone B, Gabrieli L, Sacca S, Boggian G, Fusco A, Pratola C, Bacchi-Reggiani ML, Padeletti L, Barold SS. Value of right ventricular-left ventricular interlead electrical delay to predict reverse remodelling in cardiac resynchronization therapy: the INTER-V pilot study. Europace. 2010:78-83. [pmid: 19897503].
Cabrera-Bueno F, Fernandez-Pastor J, Molina-Mora MJ, Alzueta J, Pena-Hernandez JL, Barrera A, de Teresa-Galvan E. Combined resynchronization therapy and automatic defibrillator in advanced non-ischaemic heart failure: the importance of QRS width. Europace. 2010:92-95. [pmid: 19897502].
Boriani G, Rapezzi C, Diemberger I, Gonzini L, Gorini M, Lucci D, Sinagra G, Cooke RM, Di Pasquale G, Tavazzi L, Maggioni AP. Trial-generated profiles for implantation of electrical devices in outpatients with heart failure: real-world prevalence and 1-year outcome. J Eval Clin Pract. 2010:82-91. [pmid: 19874436].
Tabereaux PB, Doppalapudi H, Kay GN, McElderry HT, Plumb VJ, Epstein AE. Limited response to cardiac resynchronization therapy in patients with concomitant right ventricular dysfunction. J Cardiovasc Electrophysiol. 2010:431-435. [pmid: 19845815].
Nazeri A, Massumi A, Rasekh A, Saeed M, Frank C, Razavi M. Cardiac resynchronization therapy in patients with right ventricular pacing-induced cardiomyopathy. Pacing Clin Electrophysiol. 2010:37-40. [pmid: 19821931].
Dickstein K, Bogale N, Priori S, Auricchio A, Cleland JG, Gitt A, Limbourg T, Linde C, van Veldhuisen DJ, Brugada J. The European cardiac resynchronization therapy survey. Eur Heart J. 2009:2450-2460. [pmid: 19723694].
Agha SA, Kalogeropoulos AP, Shih J, Georgiopoulou VV, Giamouzis G, Anarado P, Mangalat D, Hussain I, Book W, Laskar S, Smith AL, Martin R, Butler J. Echocardiography and risk prediction in advanced heart failure: incremental value over clinical markers. J Card Fail. 2009:586-592. [pmid: 19700135].
Magne J, Dubois M, Champagne J, Dumesnil JG, Pibarot P, Philippon F, O'Hara G, Senechal M. Usefulness of NT-pro BNP monitoring to identify echocardiographic responders following cardiac resynchronization therapy. Cardiovasc Ultrasound. 2009:39. [pmid: 19695099].
Foley PW, Stegemann B, Ng K, Ramachandran S, Proudler A, Frenneaux MP, Ng LL, Leyva F. Growth differentiation factor-15 predicts mortality and morbidity after cardiac resynchronization therapy. Eur Heart J. 2009:2749-2757. [pmid: 19666898].
Kronborg MB, Albertsen AE, Nielsen JC, Mortensen PT. Long-term clinical outcome and left ventricular lead position in cardiac resynchronization therapy. Europace. 2009:1177-1182. [pmid: 19661114].
Scuteri L, Rordorf R, Marsan NA, Landolina M, Magrini G, Klersy C, Frattini F, Petracci B, Vicentini A, Campana C, Tavazzi L, Ghio S. Relevance of echocardiographic evaluation of right ventricular function in patients undergoing cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2009:1040-1049. [pmid: 19659624].
D'Andrea A, Salerno G, Scarafile R, Riegler L, Gravino R, Castaldo F, Cocchia R, Limongelli G, Romano M, Calabro P, Nigro G, Cuomo S, Bossone E, Caso P, Calabro R. Right ventricular myocardial function in patients with either idiopathic or ischemic dilated cardiomyopathy without clinical sign of right heart failure: effects of cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2009:1017-1029. [pmid: 19659622].
Caldwell JC, Contractor H, Petkar S, Ali R, Clarke B, Garratt CJ, Neyses L, Mamas MA. Atrial fibrillation is under-recognized in chronic heart failure: insights from a heart failure cohort treated with cardiac resynchronization therapy. Europace. 2009:1295-1300. [pmid: 19648586].
Kleijn SA, van Dijk J, de Cock CC, Allaart CP, van Rossum AC, Kamp O. Assessment of intraventricular mechanical dyssynchrony and prediction of response to cardiac resynchronization therapy: comparison between tissue Doppler imaging and real-time three-dimensional echocardiography. J Am Soc Echocardiogr. 2009:1047-1054. [pmid: 19647409].
Shi H, Shu X, Wang F, Cui J, Chen H, Sun B, Liu S. Longitudinal two-dimensional strain rate imaging: a potential approach to predict the response to cardiac resynchronization therapy. Int J Cardiovasc Imaging. 2009:677-687. [pmid: 19639392].
Desai H, Aronow WS, Tsai FS, Ahn C, Lai HM, Amin H, Gandhi K, Frishman WH, Cohen M, Sorbera C. Statins reduce appropriate cardioverter-defibrillator shocks and mortality in patients with heart failure and combined cardiac resynchronization and implantable cardioverter-defibrillator therapy. J Cardiovasc Pharmacol Ther. 2009:176-179. [pmid: 19617418].
Leyva F, Foley PW, Stegemann B, Ward JA, Ng LL, Frenneaux MP, Regoli F, Smith RE, Auricchio A. Development and validation of a clinical index to predict survival after cardiac resynchronisation therapy. Heart. 2009:1619-1625. [pmid: 19592389].
Delnoy PP, Ottervanger JP, Luttikhuis HO, Elvan A, Misier AR, Beukema WP, van Hemel NM. Long-term clinical response of cardiac resynchronization after chronic right ventricular pacing. Am J Cardiol. 2009:116-121. [pmid: 19576330].
Ding L, Hua W, Zhang S, Chu J, Chen K, Wang F, Chen X. Improvement of P wave dispersion after cardiac resynchronization therapy for heart failure. J Electrocardiol. 2009:334-338. [pmid: 19539810].
Delgado V, Ypenburg C, Zhang Q, Mollema SA, Fung JW, Schalij MJ, Yu CM, Bax JJ. Changes in global left ventricular function by multidirectional strain assessment in heart failure patients undergoing cardiac resynchronization therapy. J Am Soc Echocardiogr. 2009:688-694. [pmid: 19501328].
Bank AJ, Kaufman CL, Kelly AS, Burns KV, Adler SW, Rector TS, Goldsmith SR, Olivari MT, Tang C, Nelson L, Metzig A. Results of the Prospective Minnesota Study of ECHO/TDI in Cardiac Resynchronization Therapy (PROMISE-CRT) study. J Card Fail. 2009:401-409. [pmid: 19477400].
Soliman OI, Geleijnse ML, Theuns DA, van Dalen BM, Vletter WB, Jordaens LJ, Metawei AK, Al-Amin AM, ten Cate FJ. Usefulness of left ventricular systolic dyssynchrony by real-time three-dimensional echocardiography to predict long-term response to cardiac resynchronization therapy. Am J Cardiol. 2009:1586-1591. [pmid: 19463520].
Schutte F, Ludorff G, Grove R, Kranig W, Thale J. Atrioventricular node ablation is not a prerequisite for cardiac resynchronization therapy in patients with chronic atrial fibrillation. Cardiol J. 2009:246-249. [pmid: 19437399].
Kamireddy S, Agarwal SK, Adelstein E, Jain S, Saba S. Correlation of electrical and mechanical reverse remodeling after cardiac resynchronization therapy. Ann Noninvasive Electrocardiol. 2009:153-157. [pmid: 19419400].
Vatankulu MA, Goktekin O, Kaya MG, Ayhan S, Kucukdurmaz Z, Sutton R, Henein M. Effect of long-term resynchronization therapy on left ventricular remodeling in pacemaker patients upgraded to biventricular devices. Am J Cardiol. 2009:1280-1284. [pmid: 19406272].
Nordbeck P, Seidl B, Fey B, Bauer WR, Ritter O. Effect of cardiac resynchronization therapy on the incidence of electrical storm. Int J Cardiol. 2010:330-336. [pmid: 19359057].
Ding LG, Hua W, Zhang S, Chu JM, Chen KP, Wang Y, Wang FZ, Chen X. Decrease of plasma N-terminal pro beta-type natriuretic peptide as a predictor of clinical improvement after cardiac resynchronization therapy for heart failure. Chin Med J (Engl). 2009:617-621. [pmid: 19323922].
Foley PW, Muhyaldeen SA, Chalil S, Smith RE, Sanderson JE, Leyva F. Long-term effects of upgrading from right ventricular pacing to cardiac resynchronization therapy in patients with heart failure. Europace. 2009:495-501. [pmid: 19307283].
Saxon LA, Olshansky B, Volosin K, Steinberg JS, Lee BK, Tomassoni G, Guarnieri T, Rao A, Yong P, Galle E, Leigh J, Ecklund F, Bristow MR. Influence of left ventricular lead location on outcomes in the COMPANION study. J Cardiovasc Electrophysiol. 2009:764-768. [pmid: 19298563].
Mele D, Toselli T, Capasso F, Stabile G, Piacenti M, Piepoli M, Giatti S, Klersy C, Sallusti L, Ferrari R. Comparison of myocardial deformation and velocity dyssynchrony for identification of responders to cardiac resynchronization therapy. Eur J Heart Fail. 2009:391-399. [pmid: 19261620].
Borleffs CJ, Ypenburg C, van Bommel RJ, Delgado V, van Erven L, Schalij MJ, Bax JJ. Clinical importance of new-onset atrial fibrillation after cardiac resynchronization therapy. Heart Rhythm. 2009:305-310. [pmid: 19251202].
Foley PW, Chalil S, Khadjooi K, Jordan P, Smith RE, Frenneaux MP, Leyva F. Effects of cardiac resynchronization therapy in patients unselected for mechanical dyssynchrony. Int J Cardiol. 2010:51-56. [pmid: 19246108].
Castellant P, Fatemi M, Orhan E, Etienne Y, Blanc JJ. Patients with non-ischaemic dilated cardiomyopathy and hyper-responders to cardiac resynchronization therapy: characteristics and long-term evolution. Europace. 2009:350-355. [pmid: 19240110].
Antonio N, Teixeira R, Coelho L, Lourenco C, Monteiro P, Ventura M, Cristovao J, Elvas L, Goncalves L, Providencia LA. Identification of 'super-responders' to cardiac resynchronization therapy: the importance of symptom duration and left ventricular geometry. Europace. 2009:343-349. [pmid: 19240109].
Peterson PN, Daugherty SL, Wang Y, Vidaillet HJ, Heidenreich PA, Curtis JP, Masoudi FA. Gender differences in procedure-related adverse events in patients receiving implantable cardioverter-defibrillator therapy. Circulation. 2009:1078-1084. [pmid: 19221223].
Maass AH, Buck S, Nieuwland W, Brugemann J, van Veldhuisen DJ, Van Gelder IC. Importance of heart rate during exercise for response to cardiac resynchronization therapy. J Cardiovasc Electrophysiol. 2009:773-780. [pmid: 19207785].
Ypenburg C, van Bommel RJ, Borleffs CJ, Bleeker GB, Boersma E, Schalij MJ, Bax JJ. Long-term prognosis after cardiac resynchronization therapy is related to the extent of left ventricular reverse remodeling at midterm follow-up. J Am Coll Cardiol. 2009:483-490. [pmid: 19195605].
Hansky B, Vogt J, Zittermann A, Guldner H, Heintze J, Schulz U, Horstkotte D, Tenderich G, Korfer R. Cardiac resynchronization therapy: long-term alternative to cardiac transplantation?. Ann Thorac Surg. 2009:432-438. [pmid: 19161754].
D'Andrea A, Caso P, Scarafile R, Riegler L, Salerno G, Castaldo F, Gravino R, Cocchia R, Del Viscovo L, Limongelli G, Di Salvo G, Ascione L, Iengo R, Cuomo S, Santangelo L, Calabro R. Effects of global longitudinal strain and total scar burden on response to cardiac resynchronization therapy in patients with ischaemic dilated cardiomyopathy. Eur J Heart Fail. 2009:58-67. [pmid: 19147458].
Yiu KH, Lee KL, Lau CP, Siu CW, Miu KM, Lam B, Lam J, Ip MS, Tse HF. Alleviation of pulmonary hypertension by cardiac resynchronization therapy is associated with improvement in central sleep apnea. Pacing Clin Electrophysiol. 2008:1522-1527. [pmid: 19067803].
Gasparini M, Lunati M, Landolina M, Santini M, Padeletti L, Perego G, Vincenti A, Curnis A, Carboni A, Denaro A, Spotti A, Grammatico A, Regoli F, Boriani G. Electrical storm in patients with biventricular implantable cardioverter defibrillator: incidence, predictors, and prognostic implications. Am Heart J. 2008:847-854. [pmid: 19061697].
Nazeri A, Massumi A, Rasekh A, Saeed M, Frank C, Wilson JM, Lopez JA, Razavi M. Cardiac resynchronization therapy may improve symptoms of congestive heart failure in patients without electrical or mechanical dyssynchrony. Europace. 2009:86-88. [pmid: 19056743].
Knebel F, Schattke S, Bondke H, Richter C, Melzer C, Dreger H, Grohmann A, Baumann G, Borges AC. Implementation of seven echocardiographic parameters of myocardial asynchrony to improve the long-term response rate of cardiac resynchronization therapy (CRT). Cardiovasc Ultrasound. 2008:58. [pmid: 19032733].
Ypenburg C, van Bommel RJ, Delgado V, Mollema SA, Bleeker GB, Boersma E, Schalij MJ, Bax JJ. Optimal left ventricular lead position predicts reverse remodeling and survival after cardiac resynchronization therapy. J Am Coll Cardiol. 2008:1402-1409. [pmid: 18940531].
Uretsky BF, Thygesen K, Daubert JC, Erdmann E, Freemantle N, Gras D, Kappenberger L, Tavazzi L, Cleland JG. Predictors of mortality from pump failure and sudden cardiac death in patients with systolic heart failure and left ventricular dyssynchrony: results of the CARE-HF trial. J Card Fail. 2008:670-675. [pmid: 18926439].
Fatemi M, Etienne Y, Castellant P, Blanc JJ. Primary failure of cardiac resynchronization therapy: what are the causes and is it worth considering a second attempt? A single-centre experience. Europace. 2008:1308-1312. [pmid: 18772163].
Santos KR, Adragao P, Cavaco D, Morgado FB, Candeias R, Lima S, Silva JA. Diaphragmatic myopotential oversensing in pacemaker-dependent patients with CRT-D devices. Europace. 2008:1381-1386. [pmid: 18757865].
Kelarijani RB, Dadjoo Y, Chalian H, Naserbakht M, Kabir K, Saleh DK. Over-time mitral regurgitation changes following cardiac resynchronization therapy. Adv Med Sci. 2008:94-98. [pmid: 18467272].
Iler MA, Hu T, Ayyagari S, Callahan TD 4th, Civello KC, Thal SG, Wilkoff BL, Chung MK. Prognostic value of electrocardiographic measurements before and after cardiac resynchronization device implantation in patients with heart failure due to ischemic or nonischemic cardiomyopathy. Am J Cardiol. 2008:359-363. [pmid: 18237600].
Muxi A, Paredes P, Mont L, Setoain FJ, Duch J, Fuertes S, Ortin J, Diaz-Infante E, Pons F. Left ventricular function and visual phase analysis with equilibrium radionuclide angiography in patients with biventricular device. Eur J Nucl Med Mol Imaging. 2008:912-921. [pmid: 18228016].
Inage T, Yoshida T, Hiraki T, Ohe M, Takeuchi T, Nagamoto Y, Fukuda Y, Gondo T, Imaizumi T. Chronic cardiac resynchronization therapy reverses cardiac remodelling and improves invasive haemodynamics of patients with severe heart failure on optimal medical treatment. Europace. 2008:379-383. [pmid: 18227354].
Buch E, Lellouche N, De Diego C, Vaseghi M, Cesario DA, Fujimura O, Wiener I, Child JS, Boyle NG, Shivkumar K. Left ventricular apical wall motion abnormality is associated with lack of response to cardiac resynchronization therapy in patients with ischemic cardiomyopathy. Heart Rhythm. 2007:1300-1305. [pmid: 17905335].
Yannopoulos D, Lurie KG, Sakaguchi S, Milstein S, Ermis C, VanHeel L, Benditt DG. Reduced atrial tachyarrhythmia susceptibility after upgrade of conventional implanted pulse generator to cardiac resynchronization therapy in patients with heart failure. J Am Coll Cardiol. 2007:1246-1251. [pmid: 17888841].
Landolina M, Lunati M, Gasparini M, Santini M, Padeletti L, Achilli A, Bianchi S, Laurenzi F, Curnis A, Vincenti A, Valsecchi S, Denaro A. Comparison of the effects of cardiac resynchronization therapy in patients with class II versus class III and IV heart failure (from the InSync/InSync ICD Italian Registry). Am J Cardiol. 2007:1007-1012. [pmid: 17826388].
Lin G, Rea RF, Hammill SC, Hayes DL, Brady PA. Effect of cardiac resynchronisation therapy on occurrence of ventricular arrhythmia in patients with implantable cardioverter defibrillators undergoing upgrade to cardiac resynchronisation therapy devices. Heart. 2008:186-190. [pmid: 17761506].
Cha YM, Rea RF, Wang M, Shen WK, Asirvatham SJ, Friedman PA, Munger TM, Espinosa RE, Hodge DO, Hayes DL, Redfield MM. Response to cardiac resynchronization therapy predicts survival in heart failure: a single-center experience. J Cardiovasc Electrophysiol. 2007:1015-1019. [pmid: 17711439].
Sunsaneewitayakul B, Sitthisook S, Sangwatanaroj S, Prechawat S, Songmuang SB. Feasibility, safety, and mid-term efficacy of cardiac resynchronization therapy in patients with severe heart failure and ventricular conduction delay: Chulalongkorn experience. J Med Assoc Thai. 2007:1458-1466. [pmid: 17710992].
Res JC, Bokern MJ, de Cock CC, van Loenhout T, Bronzwaer PN, Spierenburg HA. The BRIGHT study: bifocal right ventricular resynchronization therapy: a randomized study. Europace. 2007:857-861. [pmid: 17684064].
Raab S, Oertel F, Weimann T, Danov V, Beyer M. Brain natriuretic peptide--a reliable parameter for the effectiveness of cardiac resynchronization therapy after coronary artery bypass grafting. Interact Cardiovasc Thorac Surg. 2006:439-443. [pmid: 17670611].
Gimelli A, Stanislao M, Valle G, Frumento P, Zanco P, Ometto R, Inglese E, Martino G, Startari U, Bertelli P, Marzullo P. Volume overload modulates effects of cardiac resynchronization therapy independently of myocardial reperfusion: results of the RESYNC study. J Cardiovasc Med (Hagerstown). 2007:575-581. [pmid: 17667027].
Samesima N, Douglas R, Tobias N, Pedrosa A, Martinelli Filho M, Ramires JA, Pastore CA. Twenty-millisecond interventricular difference as assessed by body surface potential mapping identifies patients with clinical improvement after implantation of cardiac resynchronization device. Anadolu Kardiyol Derg. 2007:213-215. [pmid: 17584728].
Sassone B, Capecchi A, Boggian G, Gabrieli L, Sacca S, Vandelli R, Petracci E, Mele D. Value of baseline left lateral wall postsystolic displacement assessed by M-mode to predict reverse remodeling by cardiac resynchronization therapy. Am J Cardiol. 2007:470-475. [pmid: 17659931].
Henneman MM, Chen J, Dibbets-Schneider P, Stokkel MP, Bleeker GB, Ypenburg C, van der Wall EE, Schalij MJ, Garcia EV, Bax JJ. Can LV dyssynchrony as assessed with phase analysis on gated myocardial perfusion SPECT predict response to CRT?. J Nucl Med. 2007:1104-1111. [pmid: 17574987].
Delnoy PP, Ottervanger JP, Luttikhuis HO, Elvan A, Misier AR, Beukema WP, van Hemel NM. Comparison of usefulness of cardiac resynchronization therapy in patients with atrial fibrillation and heart failure versus patients with sinus rhythm and heart failure. Am J Cardiol. 2007:1252-1257. [pmid: 17478153].
Michelucci A, Ricciardi G, Sofi F, Gori AM, Pirolo F, Pieragnoli P, Giaccardi M, Colella A, Porciani MC, Di Biase L, Padeletti L, Abbate R, Gensini GF. Relation of inflammatory status to major adverse cardiac events and reverse remodeling in patients undergoing cardiac resynchronization therapy. J Card Fail. 2007:207-210. [pmid: 17448418].
Nagele H, Azizi M, Castel MA. Hemodynamic changes during cardiac resynchronization therapy. Clin Cardiol. 2007:141-143. [pmid: 17385702].
Gasparini M, Auricchio A, Regoli F, Fantoni C, Kawabata M, Galimberti P, Pini D, Ceriotti C, Gronda E, Klersy C, Fratini S, Klein HH. Four-year efficacy of cardiac resynchronization therapy on exercise tolerance and disease progression: the importance of performing atrioventricular junction ablation in patients with atrial fibrillation. J Am Coll Cardiol. 2006:734-743. [pmid: 16904542].
Najem B, Unger P, Preumont N, Jansens JL, Houssiere A, Pathak A, Xhaet O, Gabriel L, Friart A, De Roy L, Vandenbossche JL, van de Borne P. Sympathetic control after cardiac resynchronization therapy: responders versus nonresponders. Am J Physiol Heart Circ Physiol. 2006:H2647-H2652. [pmid: 16844919].
Bleeker GB, Schalij MJ, Holman ER, Steendijk P, van der Wall EE, Bax JJ. Cardiac resynchronization therapy in patients with systolic left ventricular dysfunction and symptoms of mild heart failure secondary to ischemic or nonischemic cardiomyopathy. Am J Cardiol. 2006:230-235. [pmid: 16828599].
Heist EK, Taub C, Fan D, Arzola-Castaner D, Alabiad CR, Reddy VY, Mansour M, Mela T, Picard MH, Ruskin JN, Singh JP. Usefulness of a novel &quot;response score&quot; to predict hemodynamic and clinical outcome from cardiac resynchronization therapy. Am J Cardiol. 2006:1732-1736. [pmid: 16765123].
Zhang Q, Fung JW, Auricchio A, Chan JY, Kum LC, Wu LW, Yu CM. Differential change in left ventricular mass and regional wall thickness after cardiac resynchronization therapy for heart failure. Eur Heart J. 2006:1423-1430. [pmid: 16682380].
Vidal B, Sitges M, Marigliano A, Diaz-Infante E, Azqueta M, Tamborero D, Macias A, Roig E, Brugada J, Pare C, Mont L. Relation of response to cardiac resynchronization therapy to left ventricular reverse remodeling. Am J Cardiol. 2006:876-881. [pmid: 16516593].
Bleeker GB, Bax JJ, Fung JW, van der Wall EE, Zhang Q, Schalij MJ, Chan JY, Yu CM. Clinical versus echocardiographic parameters to assess response to cardiac resynchronization therapy. Am J Cardiol. 2006:260-263. [pmid: 16442375].
Tse HF, Siu CW, Lee KL, Fan K, Chan HW, Tang MO, Tsang V, Lee SW, Lau CP. The incremental benefit of rate-adaptive pacing on exercise performance during cardiac resynchronization therapy. J Am Coll Cardiol. 2005:2292-2297. [pmid: 16360061].
Waggoner AD, Faddis MN, Gleva MJ, de las Fuentes L, Davila-Roman VG. Improvements in left ventricular diastolic function after cardiac resynchronization therapy are coupled to response in systolic performance. J Am Coll Cardiol. 2005:2244-2249. [pmid: 16360053].
Brandt RR, Reiner C, Arnold R, Sperzel J, Pitschner HF, Hamm CW. Contractile response and mitral regurgitation after temporary interruption of long-term cardiac resynchronization therapy. Eur Heart J. 2006:187-192. [pmid: 16223745].
Arya A, Haghjoo M, Dehghani MR, Alasti M, Alizadeh H, Kazemi B, Sadr-Ameli MA. Effect of cardiac resynchronization therapy on the incidence of ventricular arrhythmias in patients with an implantable cardioverter-defibrillator. Heart Rhythm. 2005:1094-1098. [pmid: 16188588].
Burri H, Sunthorn H, Somsen A, Zaza S, Fleury E, Shah D, Righetti A. Optimizing sequential biventricular pacing using radionuclide ventriculography. Heart Rhythm. 2005:960-965. [pmid: 16171751].
Kies P, Leclercq C, Bleeker GB, Crocq C, Molhoek SG, Poulain C, van Erven L, Bootsma M, Zeppenfeld K, van der Wall EE, Daubert JC, Schalij MJ, Bax JJ. Cardiac resynchronisation therapy in chronic atrial fibrillation: impact on left atrial size and reversal to sinus rhythm. Heart. 2006:490-494. [pmid: 16159986].
Fung JW, Yu CM, Chan JY, Chan HC, Yip GW, Zhang Q, Sanderson JE. Effects of cardiac resynchronization therapy on incidence of atrial fibrillation in patients with poor left ventricular systolic function. Am J Cardiol. 2005:728-731. [pmid: 16125504].
Kapetanakis S, Kearney MT, Siva A, Gall N, Cooklin M, Monaghan MJ. Real-time three-dimensional echocardiography: a novel technique to quantify global left ventricular mechanical dyssynchrony. Circulation. 2005:992-1000. [pmid: 16087800].
O'Connell JW, Schreck C, Moles M, Badwar N, DeMarco T, Olgin J, Lee B, Tseng Z, Kumar U, Botvinick EH. A unique method by which to quantitate synchrony with equilibrium radionuclide angiography. J Nucl Cardiol. 2005:441-450. [pmid: 16084433].
Toff WD, Camm AJ, Skehan JD. Single-chamber versus dual-chamber pacing for high-grade atrioventricular block. N Engl J Med. 2005:145-155. [pmid: 16014884].
Santomauro M, Pace L, Duilio C, Ottaviano L, Borrelli A, Ferro A, Monteforte N, Cuocolo A, Salvatore M, Chiariello M. Left ventricular pacing in patients with heart failure: evaluation study with Fourier analysis of radionuclide ventriculography. Ital Heart J. 2004:906-911. [pmid: 15706995].
Cleland JG, Daubert JC, Erdmann E, Freemantle N, Gras D, Kappenberger L, Klein W, Tavazzi L. Baseline characteristics of patients recruited into the CARE-HF study. Eur J Heart Fail. 2005:205-214. [pmid: 15701468].
Bordachar P, Lafitte S, Reuter S, Sanders P, Jais P, Haissaguerre M, Roudaut R, Garrigue S, Clementy J. Echocardiographic parameters of ventricular dyssynchrony validation in patients with heart failure using sequential biventricular pacing. J Am Coll Cardiol. 2004:2157-2165. [pmid: 15582313].
Rossillo A, Verma A, Saad EB, Corrado A, Gasparini G, Marrouche NF, Golshayan AR, McCurdy R, Bhargava M, Khaykin Y, Burkhardt JD, Martin DO, Wilkoff BL, Saliba WI, Schweikert RA, Raviele A, Natale A. Impact of coronary sinus lead position on biventricular pacing: mortality and echocardiographic evaluation during long-term follow-up. J Cardiovasc Electrophysiol. 2004:1120-1125. [pmid: 15485432].
Nichol G, Kaul P, Huszti E, Bridges JF. Cost-effectiveness of cardiac resynchronization therapy in patients with symptomatic heart failure. Ann Intern Med. 2004:343-351. [pmid: 15353425].
Vinereanu D, Bleasdale R, Turner M, Frenneaux MP, Fraser AG. Comparison of left ventricular-biventricular pacing on ventricular synchrony, mitral regurgitation, and global left ventricular function in patients with severe chronic heart failure. Am J Cardiol. 2004:519-521. [pmid: 15325945].
Valls-Bertault V, Fatemi M, Gilard M, Pennec PY, Etienne Y, Blanc JJ. Assessment of upgrading to biventricular pacing in patients with right ventricular pacing and congestive heart failure after atrioventricular junctional ablation for chronic atrial fibrillation. Europace. 2004:438-443. [pmid: 15294269].
Kies P, Bax JJ, Molhoek SG, Bleeker GB, Zeppenfeld K, Bootsma M, St John Sutton M, van Erven L, van der Wall EE, Schalij MJ. Effect of left ventricular remodeling after cardiac resynchronization therapy on frequency of ventricular arrhythmias. Am J Cardiol. 2004:130-132. [pmid: 15219525].
Kang SJ, Song JK, Yang HS, Song JM, Kang DH, Rhee KS, Nam GB, Choi KJ, Kim JJ, Kim YH. Systolic and diastolic regional myocardial motion of pacing-induced versus idiopathic left bundle branch block with and without left ventricular dysfunction. Am J Cardiol. 2004:1243-1246. [pmid: 15135697].
Riedlbauchova L, Fridl P, Kautzner J, Peichl P. Performance of left ventricular versus biventricular pacing in chronic heart failure assessed by stress echocardiography. Pacing Clin Electrophysiol. 2004:626-631. [pmid: 15125719].
Stolen KQ, Kemppainen J, Kalliokoski KK, Hallsten K, Luotolahti M, Karanko H, Lehikoinen P, Viljanen T, Salo T, Airaksinen KE, Nuutila P, Knuuti J. Myocardial perfusion reserve and oxidative metabolism contribute to exercise capacity in patients with dilated cardiomyopathy. J Card Fail. 2004:132-140. [pmid: 15101025].
Sundell J, Engblom E, Koistinen J, Ylitalo A, Naum A, Stolen KQ, Kalliokoski R, Nekolla SG, Airaksinen KE, Bax JJ, Knuuti J. The effects of cardiac resynchronization therapy on left ventricular function, myocardial energetics, and metabolic reserve in patients with dilated cardiomyopathy and heart failure. J Am Coll Cardiol. 2004:1027-1033. [pmid: 15028362].
Vural A, Agacdiken A, Ural D, Sahin T, Kozdag G, Kahraman G, Ural E, Akbas H, Suzer K, Komsuoglu B. Effect of cardiac resynchronization therapy on left atrial reverse remodeling and spontaneous echo contrast. Tohoku J Exp Med. 2004:143-153. [pmid: 14998308].
Lafitte S, Garrigue S, Perron JM, Bordachar P, Reuter S, Jais P, Haissaguerre M, Clementy J, Roudaut R. Improvement of left ventricular wall synchronization with multisite ventricular pacing in heart failure: a prospective study using Doppler tissue imaging. Eur J Heart Fail. 2004:203-212. [pmid: 14984728].
Santos JF, Caetano F, Parreira L, Madeira J, Cardoso P, Fonseca N, Segurado F, Soares LN, Ines L. Tissue Doppler echocardiography for evaluation of patients with ventricular resynchronization therapy. Rev Port Cardiol. 2003:1363-1371. [pmid: 14768491].
Santos JF, Caetano F, Parreira L, Madeira J, Cardoso P, Fonseca N, Segurado F, Soares LN, Ines L. Effects of cardiac resynchronization therapy on right ventricular function--evaluation with tissue Doppler echocardiography. Rev Port Cardiol. 2003:1347-1355. [pmid: 14768490].
Adamson PB, Kleckner KJ, VanHout WL, Srinivasan S, Abraham WT. Cardiac resynchronization therapy improves heart rate variability in patients with symptomatic heart failure. Circulation. 2003:266-269. [pmid: 12860899].
Alonso C, Ritter P, Leclercq C, Mabo P, Bailleul C, Daubert JC. Effects of cardiac resynchronization therapy on heart rate variability in patients with chronic systolic heart failure and intraventricular conduction delay. Am J Cardiol. 2003:1144-1147. [pmid: 12714168].
Varma C, O'Callaghan P, Rowland E, Mahon NG, Mckenna W, Camm AJ, Brecker SJ. Comparison between biventricular pacing and single site pacing in patients with poor ventricular function: a hemodynamic study. Pacing Clin Electrophysiol. 2003:551-558. [pmid: 12710313].
Gasparini M, Mantica M, Galimberti P, Coltorti F, Simonini S, Ceriotti C, Gronda E. Biventricular pacing via a persistent left superior vena cava: report of four cases. Pacing Clin Electrophysiol. 2003:192-196. [pmid: 12687811].
Gasparini M, Mantica M, Galimberti P, Ceriotti C, Simonini S, Mangiavacchi M, Gronda E. Relief of drug refractory angina by biventricular pacing in heart failure. Pacing Clin Electrophysiol. 2003:181-184. [pmid: 12687808].
Grimm W, Sharkova J, Funck R, Maisch B. How many patients with dilated cardiomyopathy may potentially benefit from cardiac resynchronization therapy?. Pacing Clin Electrophysiol. 2003:155-157. [pmid: 12687803].
Nielsen JC, Bottcher M, Jensen HK, Nielsen TT, Pedersen AK, Mortensen PT. Regional myocardial perfusion during chronic biventricular pacing and after acute change of the pacing mode in patients with congestive heart failure and bundle branch block treated with an atrioventricular sequential biventricular pacemaker. Eur J Heart Fail. 2003:179-186. [pmid: 12644010].
Livanis EG, Flevari P, Theodorakis GN, Kolokathis F, Leftheriotis D, Kremastinos DT. Effect of biventricular pacing on heart rate variability in patients with chronic heart failure. Eur J Heart Fail. 2003:175-178. [pmid: 12644009].
Breithardt OA, Sinha AM, Schwammenthal E, Bidaoui N, Markus KU, Franke A, Stellbrink C. Acute effects of cardiac resynchronization therapy on functional mitral regurgitation in advanced systolic heart failure. J Am Coll Cardiol. 2003:765-770. [pmid: 12628720].
Gilligan DM, Sargent D, Ponnathpur V, Dan D, Zakaib JS, Ellenbogen KA. Echocardiographic atrioventricular interval optimization in patients with dual-chamber pacemakers and symptomatic left ventricular systolic dysfunction. Am J Cardiol. 2003:629-631. [pmid: 12615281].
Izutani H, Quan KJ, Biblo LA, Gill IS. Biventricular pacing for congestive heart failure: early experience in surgical epicardial versus coronary sinus lead placement. Heart Surg Forum. 2002:E1-E6. discussion E1-6. [pmid: 12611737].
Sogaard P, Egeblad H, Pedersen AK, Kim WY, Kristensen BO, Hansen PS, Mortensen PT. Sequential versus simultaneous biventricular resynchronization for severe heart failure: evaluation by tissue Doppler imaging. Circulation. 2002:2078-2084. [pmid: 12379577].
Ricci R, Pignalberi C, Ansalone G, Jannone E, Vaccaro MV, Denaro A, Cavaglia S, Santini M. Early and late QRS morphology and width in biventricular pacing: relationship to lead site and electrical remodeling. J Interv Card Electrophysiol. 2002:279-285. [pmid: 12154331].
Breithardt OA, Stellbrink C, Kramer AP, Sinha AM, Franke A, Salo R, Schiffgens B, Huvelle E, Auricchio A. Echocardiographic quantification of left ventricular asynchrony predicts an acute hemodynamic benefit of cardiac resynchronization therapy. J Am Coll Cardiol. 2002:536-545. [pmid: 12142123].
Porciani MC, Sabini A, Colella A, Michelucci A, Musilli N, Pieragnoli P, Padeletti L. Interatrial septum pacing avoids the adverse effect of interatrial delay in biventricular pacing: an echo-Doppler evaluation. Europace. 2002:317-324. [pmid: 12134979].
Kawaguchi M, Murabayashi T, Fetics BJ, Nelson GS, Samejima H, Nevo E, Kass DA. Quantitation of basal dyssynchrony and acute resynchronization from left or biventricular pacing by novel echo-contrast variability imaging. J Am Coll Cardiol. 2002:2052-2058. [pmid: 12084608].
Hamdan MH, Barbera S, Kowal RC, Page RL, Ramaswamy K, Joglar JA, Karimkhani V, Smith ML. Effects of resynchronization therapy on sympathetic activity in patients with depressed ejection fraction and intraventricular conduction delay due to ischemic or idiopathic dilated cardiomyopathy. Am J Cardiol. 2002:1047-1051. [pmid: 11988193].
Werling C, Weisse U, Siemon G, Kiessling AH, Rameken M, Schwacke H, Saggau W, Senges J, Seidl K. Biventricular pacing in patients with ICD: how many patients are possible candidates?. Thorac Cardiovasc Surg. 2002:67-70. [pmid: 11981703].
Saxon LA, De Marco T, Schafer J, Chatterjee K, Kumar UN, Foster E. Effects of long-term biventricular stimulation for resynchronization on echocardiographic measures of remodeling. Circulation. 2002:1304-1310. [pmid: 11901040].
Ansalone G, Giannantoni P, Ricci R, Trambaiolo P, Fedele F, Santini M. Doppler myocardial imaging to evaluate the effectiveness of pacing sites in patients receiving biventricular pacing. J Am Coll Cardiol. 2002:489-499. [pmid: 11823088].
O'Cochlain B, Delurgio D, Leon A, Langberg J. The effect of variation in the interval between right and left ventricular activation on paced QRS duration. Pacing Clin Electrophysiol. 2001:1780-1782. [pmid: 11817812].
Reuter S, Garrigue S, Barold SS, Jais P, Hocini M, Haissaguerre M, Clementy J. Comparison of characteristics in responders versus nonresponders with biventricular pacing for drug-resistant congestive heart failure. Am J Cardiol. 2002:346-350. [pmid: 11809441].
Auricchio A, Kloss M, Trautmann SI, Rodner S, Klein H. Exercise performance following cardiac resynchronization therapy in patients with heart failure and ventricular conduction delay. Am J Cardiol. 2002:198-203. [pmid: 11792342].
Breithardt OA, Stellbrink C, Franke A, Balta O, Diem BH, Bakker P, Sack S, Auricchio A, Pochet T, Salo R. Acute effects of cardiac resynchronization therapy on left ventricular Doppler indices in patients with congestive heart failure. Am Heart J. 2002:34-44. [pmid: 11773910].
Butter C, Auricchio A, Stellbrink C, Fleck E, Ding J, Yu Y, Huvelle E, Spinelli J. Effect of resynchronization therapy stimulation site on the systolic function of heart failure patients. Circulation. 2001:3026-3029. [pmid: 11748094].
Garrigue S, Reuter S, Labeque JN, Jais P, Hocini M, Shah DC, Haissaguerre M, Clementy J. Usefulness of biventricular pacing in patients with congestive heart failure and right bundle branch block. Am J Cardiol. 2001:1436-1441. A8. [pmid: 11741571].
Sogaard P, Kim WY, Jensen HK, Mortensen P, Pedersen AK, Kristensen BO, Egeblad H. Impact of acute biventricular pacing on left ventricular performance and volumes in patients with severe heart failure. A tissue doppler and three-dimensional echocardiographic study. Cardiology. 2001:173-182. [pmid: 11585992].
Gaita F, Bocchiardo M, Porciani MC, Vivalda L, Colella A, Di Donna P, Caponi D, Bruzzone M, Padeletti L. Should stimulation therapy for congestive heart failure be combined with defibrillation backup?. Am J Cardiol. 2000:165K-158K.
Best PJ, Hayes DL, Stanton MS. The potential usage of dual chamber pacing in patients with implantable cardioverter defibrillators. Pacing Clin Electrophysiol. 99:79-85.
Stankovic I, Aarones M, Smith H-J, Voros G, Kongsgaard E, Neskovic AN, Willems R, Aakhus S, Voigt J-U. Dynamic relationship of left-ventricular dyssynchrony and contractile reserve in patients undergoing cardiac resynchronization therapy. Eur. Heart. J. 2014:48-55a. [pmid: 23918757].
Barretto RBM, Piegas LS, Assef JE, Melo Neto JF, Resende TU, Moreira DA, Lebihan DC, Franca FF, Meneghelo RS, Sousa AGMR. Mechanical dyssynchrony is similar in different patterns of left bundle-branch block: A dissincronia mecanica e semelhante em diferentes padroes do bloqueio de ramo esquerdo. Arq. Bras. Cardiol. 2013:449-455. [pmid: 24061684].
Watanabe E, Kasai A, Fujii E, Yamashiro K, Brugada P. Reliability of implantable cardioverter defibrillator home monitoring in forecasting the need for regular office visits, and patient perspective: Japanese HOME-ICD study. Circ. J. 2013:2704-2711. [pmid: 23903000].
Rinaldi CA, Kranig W, Leclercq C, Kacet S, Betts T, Bordachar P, Gutleben K-J, Shetty A, Keel A, Ryu K, Farazi TG, Simon M, Naqvi TZ. Acute effects of multisite left ventricular pacing on mechanical dyssynchrony in patients receiving cardiac resynchronization therapy. J. Card. Fail. 2013:731-738. [pmid: 24263116].
Pressler A, Danner M, Esefeld K, Haller B, Scherr J, Schomig A, Halle M, Kolb C. Validity of cardiac implantable electronic devices in assessing daily physical activity. Int. J. Cardiol. 2013:1127-1130. [pmid: 23201084].
Arslan U, Balci MM, Kocaoglu I, Cimen T, Kalayci S, Temizhan A. The effects of cardiac resynchronization treatment on autonomic functions aside from functional status in heart failure: Kardiyak resenkronizasyon tedavisinin otonom sistem uzerine fonksiyonel kapasite otesinde etkileri. Anadolu Kardiyoloji Derg. 2013:439-445.
Sepsi M, Krivan L, Koza KM, Sebo M, Poloczek M, Jarkovsky J, Rybka L, Kubkova L, Vlasinova J, Spinar J. Optimization of cardiac resynchronization therapy in non-responders. Cor Vasa. 2013:E293-E300.
Rodriguez Y, Garisto J, Carrillo RG. Management of cardiac device-related infections: A review of protocol-driven care. Int. J. Cardiol. 2013:55-60. [pmid: 22033126].
Zaeem F, Giedriemiene D, Coleman C, Crespo E, Radojevic J, Zweibel S, Kluger J, Clyne CA. CRT-D therapy in patients with decompensated NYHA class-four CHF. Cardiol.Res. Pract. 2012.
Leenders GE, Lumens J, Cramer MJ, De Boeck BWL, Doevendans PA, Delhaas T, Prinzen FW. Septal deformation patterns delineate mechanical dyssynchrony and regional differences in contractility analysis of patient data using a computer model. Circ. Heart Fail. 2012:87-96. [pmid: 21980078].
Wo H-T, Chang P-C, Chen T-H, Wang C-C. Cardiac resynchronization therapy in patients with and without atrial fibrillation. Acta Cardiol. Sin. 2011:46-51.
Cappelli F, Porciani MC, Ricceri I, Perrotta L, Ricciardi G, Pieragnoli P, Paladini G, Michelucci A, Padeletti L. Tricuspid annular plane systolic excursion evaluation improves selection of cardiac resynchronization therapy patients. Clin. Cardiol. 2010:578-582. [pmid: 20842743].
Edner M, Kim Y, Hansen KN, Nissen H, Espersen G, La Rosee K, Maru F, Freemantle N, Cleland J, Sogaard P. Prevalence and inter-relationship of different Doppler measures of dyssynchrony in patients with heart failure and prolonged QRS: A report from CARE-HF. Cardiovasc. Ultrasound. 2009.
Tolosana JM, Hernandez Madrid A, Brugada J, Sitges M, Garcia Bolao I, Fernandez Lozano I, Martinez Ferrer J, Quesada A, Macias A, Marin W, Escudier JM, Gomez AA, Gimenez Alcala M, Tamborero D, Berruezo A, Mont L. Comparison of Benefits and Mortality in Cardiac Resynchronization Therapy in Patients With Atrial Fibrillation Versus Patients in Sinus Rhythm (Results of the Spanish Atrial Fibrillation and Resynchronization [SPARE] Study). Am. J. Cardiol. 2008:444-449. [pmid: 18678303].
Resynchronization therapy in patients with narrow QRS (RethinQ). ACC Cardiosource Rev. J. 2007:30.
Gasparini M, Block PC. Efficacy of CRT on exercise tolerance and disease progression: The importance of AV junction ablation in patients with atrial fibrillation. ACC Cardiosource Rev. J. 2006:39-42.
Ellery S, Pakrashi T, Paul V, Sack S. Predicting mortality and rehospitalization in heart failure patients with Home Monitoring - The Home CARE pilot study. Clin. Res. Cardiol. 2006:III/29-III/35.
Parreira L, Ferreira Santos J, Madeira J, Mendes L, Seixo F, Caetano F, Lopes C, Venancio J, Mateus A, Lopes Ines J, Mendes M. Cardiac resynchronization therapy with sequential biventricular pacing: Impact of echocardiography guided VV delay optimization on acute results: Terapeutica de ressincronizacao cardiaca com pacing biventricular sequencial: Importancia da optimizacao do intervalo VV por ecocardiografia na resposta aguda a terapeutica. Rev. Port. Cardiol. 2005:1355-1365. [pmid: 16463985].
Vogt J, Lamp B, Hansky B, Heintze J, Faber L, Guldner H, Korfer R, Horstkotte D. The Bad Oeynhausen experience. Eur. Heart. J. Suppl. 2004:D122-D127.
Vogt J, Heintze J, Lamp B, Hansky B, Horstkotte D. Standard haemodynamic measurements. Eur. Heart. J. Suppl. 2004:D29-D34.
Ammann P, Kiencke S, Schaer B, Cron TA, Sticherling C, Huldi C, Linka A, Buser P, Pfisterer M, Osswald S. Cardiac resynchronization in severe heart failure and left bundle branch block: A single centre experience. Swiss Med. Wkly. 2004:277-282. [pmid: 15243848].
Deneke T, Lawo T, Gerritse B, Lemke B. Mortality of patients with implanted cardioverter/defibrillators in relation to episodes of atrial fibrillation. Europace. 2004:151-158. [pmid: 15018875].
Auricchio A, Klein HU. Expansion of ICD indications: Resynchronization therapy and the ICD. Card. Electrophysiol. Rev. 2001:35-40.
Leclercq C, Cazeau S, Ritter P, Alonso C, Gras D, Mabo P, Lazarus A, Daubert JC. A pilot experience with permanent biventricular pacing to treat advanced heart failure. Am. Heart. J. 2000:862-870. [pmid: 11099989].
Jackson T, Sohal M, Chen Z, Child N, Sammut E, Behar J, Claridge S, Carr-White G, Razavi R, Rinaldi CA. A U-shaped type II contraction pattern in patients with strict left bundle branch block predicts super-response to cardiac resynchronization therapy. Heart Rhythm. 2014.
Krishnamoorthy A, Pokorney SD, Lewis RK, Daubert JP, Greenfield RA, Hegland DD, Milano CA, Rogers JG, Schroder JN, Patel CB, Piccini JP. Cardiac implantable electronic device removal in patients with left ventricular assist device associated infections. J. Cardiovasc. Electrophysiol. 2014.
Marechaux S, Guiot A, Castel AL, Guyomar Y, Semichon M, Delelis F, Heuls S, Ennezat P-V, Graux P, Tribouilloy C. Relationship between two-dimensional speckle-tracking septal strain and response to cardiac resynchronization therapy in patients with left ventricular dysfunction and left bundle branch block: A prospective pilot study. J. Am. Soc. Echocardiogr. 2014:501-511. [pmid: 24513239].
Stankovic I, Aarones M, Smith H-J, Voros G, Kongsgaard E, Neskovic AN, Willems R, Aakhus S, Voigt J-U. Dynamic relationship of left-ventricular dyssynchrony and contractile reserve in patients undergoing cardiac resynchronization therapy. Eur. Heart. J. 2014:48-55a. [pmid: 23918757].
Lalonde M, Wells RG, Birnie D, Ruddy TD, Wassenaar R. Development and optimization of SPECT gated blood pool cluster analysis for the prediction of CRT outcome. Med. Phys. 2014.
Noda T, Kurita T, Nitta T, Abe H, Watanabe S, Furushima H, Matsumoto N, Toyoshima T, Shimizu A, Mitamura H, Ohe T, Aizawa Y. Appropriate duration of driving restrictions after inappropriate therapy from implantable cardiac shock devices - Interim analysis of the Nippon Storm Study. Circ. J. 2014:1989-1991. [pmid: 25030300].
Wojciechowska C, Tomasik A, Gala A, Kubiak G, Krzemien-Wolska K, Kawecki D, Nowalany-Kozielska E, Jachec W. Hemodynamic effects after six-month CRT and after acute discontinuation evaluated by RHC. Exp. Clin. Cardiol. 2014:3932-3952.
Lenarczyk R, Jedrzejczyk-Patej E, Mazurek M, Szulik M, Kowalski O, Pruszkowska P, Sokal A, Sredniawa B, Boidol J, Kowalczyk J, Podolecki T, Mencel G, Kalarus Z. Quality of Life in Cardiac Resynchronization Recipients: Association with Response and Impact on Outcome. Pacing Clin Electrophysiol. 2014.
Varma N. Left ventricular electrical activation during right ventricular pacing in heart failure patients with LBBB: Visualization by electrocardiographic imaging and implications for cardiac resynchronization therapy. J Electrocardiol. 2014.
Hurlimann D, Schmidt S, Seifert B, Saguner AM, Hindricks G, Luscher TF, Ruschitzka F, Steffel J. Outcome of super-responders to cardiac resynchronization therapy defined by endpoint-derived parameters of left ventricular remodeling: a two-center retrospective study. Clin Res Cardiol. 2014.
Engels EB, Vegh EM, VAN Deursen CJ, Vernooy K, Singh JP, Prinzen FW. T-Wave Area Predicts Response to Cardiac Resynchronization Therapy in Patients with Left Bundle Branch Block. J Cardiovasc Electrophysiol. 2014.
Khazanie P, Hammill BG, Qualls LG, Fonarow GC, Hammill SC, Heidenreich PA, Al-Khatib SM, Piccini JP, Masoudi FA, Peterson PN, Curtis JP, Hernandez AF, Curtis LH. Clinical Effectiveness of Cardiac Resynchronization Therapy vs Medical Therapy Alone Among Patients With Heart Failure: An Analysis of the ICD and ADHERE National Registries. Circ Heart Fail. 2014.
Schmitz B, DeMaria R, Gatsios D, Chrysanthakopoulou T, Landolina M, Gasparini M, Campolo J, Parolini M, Sanzo A, Galimberti P, Bianchi M, Lenders M, Brand E, Parodi O, Lunati M, Brand SM. Identification of Genetic Markers for Treatment Success in Heart Failure Patients: Insight from Cardiac Resynchronization Therapy. Circ Cardiovasc Genet. 2014.
Schuchert A, Muto C, Maounis T, Ella RO, Polauck A, Padeletti L. Relationship between pre-implant ejection fraction and outcome after cardiac resynchronization therapy in symptomatic patients. Acta Cardiol. 2014:424-432. [pmid: 25181918].
Verhagen MP, van Boven N, Ruiter JH, Kimman GJ, Tahapary GJ, Umans VA. Follow-up of implantable cardioverter-defibrillator therapy: comparison of coronary artery disease and dilated cardiomyopathy. Neth Heart J. 2014:431-437. [pmid: 25169578].
Linde C, Stahlberg M, Benson L, Braunschweig F, Edner M, Dahlstrom U, Alehagen U, Lund LH. Gender, underutilization of cardiac resynchronization therapy, and prognostic impact of QRS prolongation and left bundle branch block in heart failure. Europace. 2014.
Ruwald AC, Kutyifa V, Ruwald MH, Solomon S, Daubert JP, Jons C, Brenyo A, McNitt S, Do D, Tanabe K, Al-Ahmad A, Wang P, Moss AJ, Zareba W. The association between biventricular pacing and cardiac resynchronization therapy-defibrillator efficacy when compared with implantable cardioverter defibrillator on outcomes and reverse remodelling. Eur Heart J. 2014.
Sohal M, Duckett SG, Zhuang X, Shi W, Ginks M, Shetty A, Sammut E, Kozerke S, Niederer S, Smith N, Ourselin S, Rinaldi C, Rueckert D, Carr-White G, Razavi R. A prospective evaluation of cardiovascular magnetic resonance measures of dyssynchrony in the prediction of response to cardiac resynchronization therapy. J Cardiovasc Magn Reson. 2014:58. [pmid: 25084814].
Truong QA, Januzzi JL, Szymonifka J, Thai WE, Wai B, Lavender Z, Sharma U, Sandoval RM, Grunau ZS, Basnet S, Babatunde A, Ajijola OA, Min JK, Singh JP. Coronary sinus biomarker sampling compared to peripheral venous blood for predicting outcomes in patients with severe heart failure undergoing cardiac resynchronization therapy: The BIOCRT study. Heart Rhythm. 2014.
Mitrani RD, Sager SJ, Moscucci M, Cogan J, Myerburg RJ. Transient variations of transthoracic impedance as a predictor of heart failure and death in patients with implanted defibrillators. Int J Cardiol. 2014:473-477. [pmid: 25012496].
Kutyifa V, Stockburger M, Daubert JP, Holmqvist F, Olshansky B, Schuger C, Klein H, Goldenberg I, Brenyo A, McNitt S, Merkely B, Zareba W, Moss AJ. PR interval identifies clinical response in patients with non-left bundle branch block: a Multicenter Automatic Defibrillator Implantation Trial-Cardiac Resynchronization Therapy substudy. Circ Arrhythm Electrophysiol. 2014:645-651. [pmid: 24963007].
Steffel J, Hurlimann A, Starck C, Krasniqi N, Schmidt S, Luscher TF, Duru F, Ruschitzka F, Holzmeister J, Hurlimann D. Long-term performance of modern coronary sinus leads in cardiac resynchronization therapy. Indian Pacing Electrophysiol J. 2014:112-120. [pmid: 24948850].
Derval N, Bordachar P, Lim HS, Sacher F, Ploux S, Laborderie J, Steendijk P, Deplagne A, Ritter P, Garrigue S, Denis A, Hocini M, Haissaguerre M, Clementy J, Jais P. Impact of Pacing Site on QRS Duration and Its Relationship to Hemodynamic Response in Cardiac Resynchronization Therapy for Congestive Heart Failure. J Cardiovasc Electrophysiol. 2014:1012-1020. [pmid: 24891271].
Mittal S, Aktas MK, Moss AJ, McNitt S, Kutyifa V, Steinberg JS, Zareba W. The Impact of Nonsustained Ventricular Tachycardia on Reverse Remodeling, Heart Failure, and Treated Ventricular Tachyarrhythmias in MADIT-CRT. J Cardiovasc Electrophysiol. 2014:1082-1087. [pmid: 24862906].
Sharma AK, Vegh EM, Kandala J, Orencole M, Januszkiewicz L, Bose A, Miller A, Parks KA, Heist EK, Singh JP. Usefulness of hyponatremia as a predictor for adverse events in patients with heart failure receiving cardiac resynchronization therapy. Am J Cardiol. 2014:83-87. [pmid: 24852916].
Ousdigian KT, Borek PP, Koehler JL, Heywood JT, Ziegler PD, Wilkoff BL. The epidemic of inadequate biventricular pacing in patients with persistent or permanent atrial fibrillation and its association with mortality. Circ Arrhythm Electrophysiol. 2014:370-376. [pmid: 24838004].
Setoguchi S, Warner Stevenson L, Stewart GC, Bhatt DL, Epstein AE, Desai M, Williams LA, Chen CY. Influence of healthy candidate bias in assessing clinical effectiveness for implantable cardioverter-defibrillators: cohort study of older patients with heart failure. BMJ. 2014:g2866. [pmid: 24812112].
Holmqvist F, Hellkamp AS, Lee KL, Lamas GA, Daubert JP. Adverse Effects of First-Degree AV-Block in Patients with Sinus Node Dysfunction: Data from the Mode Selection Trial. Pacing Clin Electrophysiol. 2014:1111-1119. [pmid: 24797760].
Schneider PM, Pellegrini CN, Wang Y, Fein AS, Reynolds MR, Curtis JP, Masoudi FA, Varosy PD. Prevalence of guideline-directed medical therapy among patients receiving cardiac resynchronization therapy defibrillator implantation in the National Cardiovascular Data Registry during the years 2006 to 2008. Am J Cardiol. 2014:2052-2056. [pmid: 24793671].
Brunet-Bernard A, Marechaux S, Fauchier L, Guiot A, Fournet M, Reynaud A, Schnell F, Leclercq C, Mabo P, Donal E. Combined score using clinical, electrocardiographic, and echocardiographic parameters to predict left ventricular remodeling in patients having had cardiac resynchronization therapy six months earlier. Am J Cardiol. 2014:2045-2051. [pmid: 24793667].
Wang J, Su Y, Bai J, Wang W, Qin S, Ge J. Elevated pulmonary artery pressure predicts poor outcome after cardiac resynchronization therapy. J Interv Card Electrophysiol. 2014:171-178. [pmid: 24728706].
Facchini E, Varalda M, Sartori C, Burkhoff D, Marino PN. Systolic heart failure and cardiac resynchronization therapy: a focus on diastole. Int J Cardiovasc Imaging. 2014:897-905. [pmid: 24706254].
Varma N, Manne M, Nguyen D, He J, Niebauer M, Tchou P. Probability and magnitude of response to cardiac resynchronization therapy according to QRS duration and gender in nonischemic cardiomyopathy and LBBB. Heart Rhythm. 2014:1139-1147. [pmid: 24704570].
Brouwers C, Versteeg H, Meine M, Heijnen CJ, Kavelaars AM, Pedersen SS, Mommersteeg PM. Association between brain natriuretic peptide, markers of inflammation and the objective and subjective response to cardiac resynchronization therapy. Brain Behav Immun. 2014:211-218. [pmid: 24704567].
Padeletti L, Modesti PA, Cartei S, Checchi L, Ricciardi G, Pieragnolia P, Sacchi S, Padeletti M, Alterini B, Pantaleo P, Hu X, Tenori L, Luchinat C. Metabolomic does not predict response to cardiac resynchronization therapy in patients with heart failure. J Cardiovasc Med (Hagerstown). 2014:295-300. [pmid: 24699011].
Chan DD, Wu KC, Loring Z, Galeotti L, Gerstenblith G, Tomaselli G, Weiss RG, Wagner GS, Strauss DG. Comparison of the relation between left ventricular anatomy and QRS duration in patients with cardiomyopathy with versus without left bundle branch block. Am J Cardiol. 2014:1717-1722. [pmid: 24698465].
Reitan C, Bakos Z, Platonov PG, Hoijer CJ, Brandt J, Wang L, Borgquist R. Patient-assessed short-term positive response to cardiac resynchronization therapy is an independent predictor of long-term mortality. Europace. 2014.
Zanon F, Baracca E, Pastore G, Fraccaro C, Roncon L, Aggio S, Noventa F, Mazza A, Prinzen F. Determination of the longest intrapatient left ventricular electrical delay may predict acute hemodynamic improvement in patients after cardiac resynchronization therapy. Circ Arrhythm Electrophysiol. 2014:377-383. [pmid: 24668162].
Adelstein E, Schwartzman D, Bazaz R, Jain S, Gorcsan J 3rd, Saba S. Outcomes in pacemaker-dependent patients upgraded from conventional pacemakers to cardiac resynchronization therapy-defibrillators. Heart Rhythm. 2014:1008-1014. [pmid: 24657426].
Vegh EM, Kandala J, Orencole M, Upadhyay GA, Sharma A, Miller A, Merkely B, Parks KA, Singh JP. Device-measured physical activity versus six-minute walk test as a predictor of reverse remodeling and outcome after cardiac resynchronization therapy for heart failure. Am J Cardiol. 2014:1523-1528. [pmid: 24641966].
Adelstein E, Alam MB, Schwartzman D, Jain S, Marek J, Gorcsan J, Saba S. Effect of echocardiography-guided left ventricular lead placement for cardiac resynchronization therapy on mortality and risk of defibrillator therapy for ventricular arrhythmias in heart failure patients (from the Speckle Tracking Assisted Resynchronization Therapy for Electrode Region. Am J Cardiol. 2014:1518-1522. [pmid: 24630387].
Bilchick KC, Kuruvilla S, Hamirani YS, Ramachandran R, Clarke SA, Parker KM, Stukenborg GJ, Mason P, Ferguson JD, Moorman JR, Malhotra R, Mangrum JM, Darby AE, Dimarco J, Holmes JW, Salerno M, Kramer CM, Epstein FH. Impact of mechanical activation, scar, and electrical timing on cardiac resynchronization therapy response and clinical outcomes. J Am Coll Cardiol. 2014:1657-1666. [pmid: 24583155].
Gabrielli L, Marincheva G, Bijnens B, Doltra A, Tolosana JM, Borras R, Castel MA, Berruezo A, Brugada J, Mont L, Sitges M. Septal flash predicts cardiac resynchronization therapy response in patients with permanent atrial fibrillation. Europace. 2014:1342-1349. [pmid: 24576973].
Ogano M, Iwasaki YK, Tanabe J, Takagi H, Umemoto T, Hayashi M, Miyauchi Y, Shimizu W. Cardiac resynchronization therapy restored ventricular septal myocardial perfusion and enhanced ventricular remodeling in patients with nonischemic cardiomyopathy presenting with left bundle branch block. Heart Rhythm. 2014:836-841. [pmid: 24561161].
Shalaby AA, Brumberg GE, Pointer L, Bekelman DB, Rumsfeld JS, Yang Y, Pellegrini CN, Heidenreich PA, Keung E, Massie BM, Varosy PD. Depression and outcome among veterans with implantable cardioverter defibrillators with or without cardiac resynchronization therapy capability. Pacing Clin Electrophysiol. 2014:994-1001. [pmid: 24520992].
Plank B, Kutyifa V, Moss AJ, Huang DT, Ruwald AC, McNitt S, Polonsky B, Zareba W, Goldenberg I, Aktas MK. Smoking is associated with an increased risk of first and recurrent ventricular tachyarrhythmias in ischemic and nonischemic patients with mild heart failure: a MADIT-CRT substudy. Heart Rhythm. 2014:822-827. [pmid: 24509214].
D'Onofrio A, Botto G, Mantica M, LA Rosa C, Occhetta E, Verlato R, Molon G, Ammendola E, Villani GQ, Bongiorni MG, Bianchi V, Gelmini GP, Valsecchi S, Ciardiello C. Incremental value of larger interventricular conduction time in improving cardiac resynchronization therapy outcome in patients with different QRS duration. J Cardiovasc Electrophysiol. 2014:500-506. [pmid: 24494797].
Rickard J, Cheng A, Spragg D, Green A, Leff B, Tang W, Cantillon D, Baranowski B, Wilkoff BL, Tchou P. Survival in octogenarians undergoing cardiac resynchronization therapy compared to the general population. Pacing Clin Electrophysiol. 2014:740-744. [pmid: 24471992].
Poller WC, Dreger H, Schwerg M, Bondke H, Melzer C. Not left ventricular lead position, but the extent of immediate asynchrony reduction predicts long-term response to cardiac resynchronization therapy. Clin Res Cardiol. 2014:457-466. [pmid: 24468897].
Merlo M, Pivetta A, Pinamonti B, Stolfo D, Zecchin M, Barbati G, Di Lenarda A, Sinagra G. Long-term prognostic impact of therapeutic strategies in patients with idiopathic dilated cardiomyopathy: changing mortality over the last 30 years. Eur J Heart Fail. 2014:317-324. [pmid: 24464640].
Auger D, Hoke U, Thijssen J, Abate E, Yiu KH, Ewe SH, Witkowski TG, Leong DP, Holman ER, Ajmone Marsan N, Schalij MJ, Bax JJ, Delgado V. Effect of cardiac resynchronization therapy on the sequence of mechanical activation assessed by two-dimensional radial strain imaging. Am J Cardiol. 2014:982-987. [pmid: 24462070].
Frigerio M, Lunati M, Pasqualucci D, Vargiu S, Foti G, Pedretti S, Vittori C, Cattafi G, Magenta G, Campo C, Bisetti S, Mercuro G. Left ventricular ejection fraction overcrossing 35% after one year of cardiac resynchronization therapy predicts long term survival and freedom from sudden cardiac death: single center observational experience. Int J Cardiol. 2014:64-71. [pmid: 24456869].
Antonio N, Soares A, Carvalheiro T, Fernandes R, Paiva A, Ventura M, Cristovao J, Elvas L, Goncalves L, Providencia LA, Ribeiro CF, Pego GM. Circulating endothelial progenitor cells as a predictor of response to cardiac resynchronization therapy: the missing piece of the puzzle?. Pacing Clin Electrophysiol. 2014:731-739. [pmid: 24383551].
Aktas MK, Zareba W, Huang DT, McNitt S, Polonsky S, Chen L, Stockburger M, Merkely B, Moss AJ, Kutyifa V. The effect of weight loss on clinical outcomes in patients implanted with a cardiac resynchronization therapy device-A MADIT-CRT substudy. J Card Fail. 2014:183-189. [pmid: 24361804].
Bose A, Kandala J, Upadhyay GA, Riedl L, Ahmado I, Padmanabhan R, Gewirtz H, Mulligan LJ, Singh JP. Impact of myocardial viability and left ventricular lead location on clinical outcome in cardiac resynchronization therapy recipients with ischemic cardiomyopathy. J Cardiovasc Electrophysiol. 2014:507-513. [pmid: 24350650].
Mittal S, Shaw RE, Michel K, Palekar R, Arshad A, Musat D, Preminger M, Sichrovsky T, Steinberg JS. Cardiac implantable electronic device infections: incidence, risk factors, and the effect of the AigisRx antibacterial envelope. Heart Rhythm. 2014:595-601. [pmid: 24333543].
Chang PC, Wo HT, Chen TH, Wu D, Lin FC, Wang CC. Remote past left ventricular function before chronic right ventricular pacing predicts responses to cardiac resynchronization therapy upgrade. Pacing Clin Electrophysiol. 2014:454-463. [pmid: 24251726].
Bortnik M, Degiovanni A, Dell'era G, Cavallino C, Occhetta E, Marino P. Prevalence of ventricular arrhythmias in patients with cardiac resynchronization therapy without back-up ICD: a single-center experience. J Cardiovasc Med (Hagerstown). 2014:301-306. [pmid: 23811840].
Knackstedt C, Arndt M, Mischke K, Marx N, Nieman F, Kunert HJ, Schauerte P, Norra C. Depression, psychological distress, and quality of life in patients with cardioverter defibrillator with or without cardiac resynchronization therapy. Heart Vessels. 2014:364-374. [pmid: 23732755].
Perrotta L, Xhaferi B, Chiostri M, Pieragnoli P, Ricciardi G, Di Biase L, Natale A, Ricceri I, Biria M, Lakkireddy D, Valleggi A, Emdin M, Michelotti F, Mascioli G, Pandozi A, Santini M, Padeletti L. Effects of smoking in patients treated with cardiac resynchronization therapy. Intern Emerg Med. 2014:311-318. [pmid: 23250544].
Marek JJ, Saba S, Onishi T, Ryo K, Schwartzman D, Adelstein EC, Gorcsan IIIJ. Usefulness of echocardiographically guided left ventricular lead placement for cardiac resynchronization therapy in patients with intermediate QRS width and non-left bundle branch block morphology. American journal of cardiology. 2014:107-116. [pmid: 24169014].
Skali H, Dwyer EM, Goldstein R, Haigney M, Krone R, Kukin M, Lichstein E, McNitt S, Moss AJ, Pfeffer MA, Solomon SD. Prognosis and response to therapy of first inpatient and outpatient heart failure event in a heart failure clinical trial: MADIT-CRT. European journal of heart failure. 2014:560-565. [pmid: 24578164].

## Single case study

Shah BN, Bethell HW, Senior R. Pacemaker-related reversible right heart failure. Postgrad Med J. 2013:486-487. [pmid: 23681000].
Itoh M, Yoshida A, Takei A, Hirata K. Electrical storm after cardiac resynchronization therapy suppressed by triple-site biventricular pacing and atrioventricular nodal ablation. Heart Rhythm. 2012:2059-2062. [pmid: 22863886].
Oginosawa Y, Nogami A, Soejima K, Aonuma K, Kubota S, Sato T, Sugiyasu A, Yoshida K, Kowase S, Sakamaki M, Kurosaki K, Kato K. Effect of cardiac resynchronization therapy in isolated ventricular noncompaction in adults: follow-up of four cases. J Cardiovasc Electrophysiol. 2008:935-938. [pmid: 18399967].
Rao BH, Kalavakolanu S, Chandrasekar K, Sastry BK, Narasimhan C. Cardiac resynchronization therapy in hemodynamically unstable heart failure patients. Indian Heart J. 2007:185-187. [pmid: 19122255].
Toggweiler S, Zuber M, Erne P. Optimization of atrioventricular and interventricular delay with acoustic cardiography in biventricular pacing. Congest Heart Fail. 2006:37-40. [pmid: 16894273].
Dizon J, Horn E, Neglia J, Medina N, Garan H. Loss of left bundle branch block following biventricular pacing therapy for heart failure: evidence for electrical remodeling?. J Interv Card Electrophysiol. 2004:47-50. [pmid: 14739749].
Akiyama M, Kaneko Y, Taniguchi Y, Kurabayashi M. Pacemaker syndrome associated with a biventricular pacing system. J Cardiovasc Electrophysiol. 2002:1061-1062. [pmid: 12435200].
Breithardt OA, Kuhl HP, Stellbrink C. Acute effects of resynchronisation treatment on functional mitral regurgitation in dilated cardiomyopathy. Heart. 2002:440. [pmid: 12231617].
Chamoun AJ, Lenihan DJ, McCulloch M, Ahmad M, Sheahan RG. Resynchronization therapy in dilated cardiomyopathy: confirmation of hemodynamic improvement with real-time three-dimensional echocardiography. Circulation. 2001:E98-E98. [pmid: 11352896].
Sbragia P, Nait-Saidi L, Alexandre Trigano J, Saadjian A, Barnay P, Levy S. Intra-atrial thrombosis and pulmonary embolism complicating pacemaker leads for cardiac resynchronization therapy. J. Intervent. Card. Electrophysiol. 2003:25-27.
Steffel J, Ruschitzka F. Superresponse to cardiac resynchronization therapy. Circulation. 2014:87-90. [pmid: 24982120].

## Addresses only effectiveness; not an RCT

Thoren E, Kesek M, Jideus L. The effect of concomitant cardiac resynchronization therapy on quality of life in patients with heart failure undergoing cardiac surgery. Open Cardiovasc Med J. 2014:18-22. [pmid: 24665351].
Killu AM, Grupper A, Friedman PA, Powell BD, Asirvatham SJ, Espinosa RE, Luria D, Rozen G, Buber Y, Lee YH, Webster T, Brooke KL, Hodge DO, Wiste HJ, Glikson M, Cha YM. Predictors and Outcomes of 'Super-Response' to Cardiac Resynchronization Therapy. J Card Fail. 2014.
Sohinki D, Ho J, Srinivasan N, Collins LJ, Obel OA. Outcomes after atrioventricular node ablation and biventricular pacing in patients with refractory atrial fibrillation and heart failure: a comparison between non-ischaemic and ischaemic cardiomyopathy. Europace. 2014.
Sardu C, Marfella R, Santulli G. Impact of Diabetes Mellitus on the Clinical Response to Cardiac Resynchronization Therapy in Elderly People. J Cardiovasc Transl Res. 2014.
Rickard J, Cheng A, Spragg D, Green A, Leff B, Tang W, Cantillon D, Baranowski B, Wilkoff BL, Tchou P. Survival in Octogenarians Undergoing Cardiac Resynchronization Therapy Compared to the General Population. Pacing Clin Electrophysiol. 2014.
Bremont C, Lim P, Elbaz N, Damy T, Gueret P, Dubois-Rande JL, Wallick DW, Lellouche N. Cardiac Resynchronization Therapy Plus Coupled Pacing Improves Acutely Myocardial Function in Heart Failure Patients. Pacing Clin Electrophysiol. 2014.
Ford J, Sears S, Ramza B, Reynolds DW, Nguyen P, Fedewa M, House J, Kennedy P, Thompson R, Murray C. The Registry Evaluating Functional Outcomes of Resynchronization Management (REFORM): quality of life and psychological functioning in patients receiving cardiac resynchronization therapy. J Cardiovasc Electrophysiol. 2014:43-51. [pmid: 24102945].
Knackstedt C, Arndt M, Mischke K, Marx N, Nieman F, Kunert HJ, Schauerte P, Norra C. Depression, psychological distress, and quality of life in patients with cardioverter defibrillator with or without cardiac resynchronization therapy. Heart Vessels. 2013.
Stanciu AE, Vatasescu RG, Stanciu MM, Iorgulescu C, Vasile AI, Dorobantu M. Cardiac resynchronization therapy in patients with chronic heart failure is associated with anti-inflammatory and anti-remodeling effects. Clin Biochem. 2013:230-234. [pmid: 23159290].
Eickholt C, Siekiera M, Kirmanoglou K, Rodenbeck A, Heussen N, Schauerte P, Lichtenberg A, Balzer J, Rassaf T, Perings S, Kelm M, Shin DI, Meyer C. Improvement of left ventricular function under cardiac resynchronization therapy goes along with a reduced incidence of ventricular arrhythmia. PLoS One. 2012:e48926. [pmid: 23152822].
Fonarow GC, Albert NM, Curtis AB, Gheorghiade M, Liu Y, Mehra MR, O'Connor CM, Reynolds D, Walsh MN, Yancy CW. Incremental Reduction in Risk of Death Associated With Use of Guideline-Recommended Therapies in Patients With Heart Failure: A Nested Case-Control Analysis of IMPROVE HF. J Am Heart Assoc. 2012:16-26. [pmid: 23130115].
Aly MF, Kleijn SA, de Boer K, Abd El-Hady YA, Sorour KA, Kandil HI, van Rossum AC, Kamp O. Comparison of three-dimensional echocardiographic software packages for assessment of left ventricular mechanical dyssynchrony and prediction of response to cardiac resynchronization therapy. Eur Heart J Cardiovasc Imaging. 2013:700-710. [pmid: 23111693].
Celikyurt U, Agacdiken A, Sahin T, Al N, Kozdag G, Vural A, Ural D. Number of leads with fragmented QRS predicts response to cardiac resynchronization therapy. Clin Cardiol. 2013:36-39. [pmid: 23081693].
Guha K, Mantziari L, Sharma R, McDonagh TA, Gibson D, Duncan AM. A reduction in total isovolumic time with cardiac resynchronisation therapy is a predictor of clinical outcomes. Int J Cardiol. 2013:382-387. [pmid: 23041011].
Verbrugge FH, Dupont M, Vercammen J, Jacobs L, Verhaert D, Vandervoort P, Tang WH, Mullens W. Time from emerging heart failure symptoms to cardiac resynchronisation therapy: impact on clinical response. Heart. 2013:314-319. [pmid: 23038789].
Kamioka M, Suzuki H, Yamada S, Kamiyama Y, Saitoh S, Takeishi Y. High sensitivity C-reactive protein predicts nonresponders and cardiac deaths in severe heart failure patients after CRT implantation. Int Heart J. 2012:306-312. [pmid: 23038092].
Arao K, Fujiwara T, Sakakura K, Wada H, Sugawara Y, Suga C, Ako J, Ishikawa SE, Momomura S. Hyponatremia as a predictor for worsening heart failure in patients receiving cardiac resynchronization therapy. Circ J. 2013:116-122. [pmid: 23018767].
Kusiak A, Wilinski J, Wojciechowska W, Jastrzebski M, Sondej T, Bacior B, Kloch-Badelek M, Czarnecka D. Effects of biventricular pacing on right ventricular function assessed by standard echocardiography. Kardiol Pol. 2012:883-888. [pmid: 22992994].
Kandala J, Upadhyay GA, Altman RK, Bose A, Heist EK, Mela T, Singh JP. Electrical delay in apically positioned left ventricular leads and clinical outcome after cardiac resynchronization therapy. J Cardiovasc Electrophysiol. 2013:182-187. [pmid: 22966852].
Abu Sham'a R, Buber J, Grupper A, Nof E, Kuperstein R, Luria D, Feinberg MS, Eldar M, Glikson M. Effects of tricuspid valve regurgitation on clinical and echocardiographic outcome in patients with cardiac resynchronization therapy. Europace. 2013:266-272. [pmid: 22952208].
Park MY, Altman RK, Orencole M, Kumar P, Parks KA, Heist KE, Singh JP, Picard MH. Characteristics of responders to cardiac resynchronization therapy: the impact of echocardiographic left ventricular volume. Clin Cardiol. 2012:777-780. [pmid: 22886700].
Kaneshiro T, Suzuki H, Yamada S, Kamiyama Y, Saitoh S, Takeishi Y. Intrathoracic impedance changes reflect reverse left ventricular remodeling in response to cardiac resynchronization therapy in chronic heart failure patients. Int Heart J. 2012:249-252. [pmid: 22878804].
Praus R, Haman L, Tauchman M, Blaha V, Parizek P. Cardiac resynchronization therapy in clinical responders: right ventricular echocardiographic changes at mid-term follow-up. Acta Cardiol. 2012:311-316. [pmid: 22870739].
Hosoda J, Ishikawa T, Matsushita K, Matsumoto K, Kimura Y, Miyamoto M, Ogawa H, Takamura T, Sugano T, Ishigami T, Uchino K, Kimura K, Umemura S. Impact of renal insufficiency on long-term clinical outcome in patients with heart failure treated by cardiac resynchronization therapy. J Cardiol. 2012:301-305. [pmid: 22763383].
Kloch Badelek M, Klocek M, Czarnecka D, Wojciechowska W, Wilinski J, Kawecka Jaszcz K. Impact of cardiac resynchronisation therapy on physical ability and quality of life in patients with chronic heart failure. Kardiol Pol. 2012:581-588. [pmid: 22718376].
Celikyurt U, Agacdiken A, Sahin T, Kozdag G, Vural A, Ural D. Association between red blood cell distribution width and response to cardiac resynchronization therapy. J Interv Card Electrophysiol. 2012:215-218. [pmid: 22688952].
Himmel F, Reppel M, Mortensen K, Schunkert H, Bode F. A strategy to achieve CRT response in permanent atrial fibrillation without obligatory atrioventricular node ablation. Pacing Clin Electrophysiol. 2012:943-947. [pmid: 22650352].
Shah RV, Altman RK, Park MY, Zilinski J, Leyton-Mange J, Orencole M, Picard MH, Barrett CD, Heist EK, Upadhyay G, Das R, Singh JP, Das S. Usefulness of hemoglobin A(1c) to predict outcome after cardiac resynchronization therapy in patients with diabetes mellitus and heart failure. Am J Cardiol. 2012:683-688. [pmid: 22632827].
Kreuz J, Horlbeck F, Linhart M, Mellert F, Fimmers R, Schrickel J, Nickenig G, Schwab JO. Independent predictors of mortality in patients with advanced heart failure treated by cardiac resynchronization therapy. Europace. 2012:1596-1601. [pmid: 22611058].
Malagoli A, Rossi L, Franchi F, Piepoli MF, Malavasi V, Casali E, Modena MG, Villani GQ. Effect of cardiac resynchronization therapy on left atrial reverse remodeling: role of echocardiographic AV delay optimization. Int J Cardiol. 2013:1456-1460. [pmid: 22560916].
Leenders GE, De Boeck BW, Teske AJ, Meine M, Bogaard MD, Prinzen FW, Doevendans PA, Cramer MJ. Septal rebound stretch is a strong predictor of outcome after cardiac resynchronization therapy. J Card Fail. 2012:404-412. [pmid: 22555272].
Bank AJ, Rischall A, Gage RM, Burns KV, Kubo SH. Comparison of cardiac resynchronization therapy outcomes in patients with New York Heart Association functional class I/II versus III/IV heart failure. J Card Fail. 2012:373-378. [pmid: 22555266].
Celebi O, Knaus T, Blaschke F, Habedank D, Dohner W, Nitardy A, Stockburger M. Extraordinarily favorable left ventricular reverse remodeling through long-term cardiac resynchronization: super-response to cardiac resynchronization. Pacing Clin Electrophysiol. 2012:870-876. [pmid: 22553930].
Smith T, Levy WC, Schaer BA, Balk AH, Sticherling C, Jordaens L, Theuns DA. Performance of the Seattle Heart Failure Model in implantable defibrillator patients treated with cardiac resynchronization therapy. Am J Cardiol. 2012:398-402. [pmid: 22516524].
Stefan L, Sedlacek K, Cerna D, Kryze L, Vancura V, Marek T, Kautzner J. Small left atrium and mild mitral regurgitation predict super-response to cardiac resynchronization therapy. Europace. 2012:1608-1614. [pmid: 22490374].
Zizek D, Cvijic M, Tasic J, Jan M, Frljak S, Zupan I. Effect of cardiac resynchronization therapy on beat-to-beat T-wave amplitude variability. Europace. 2012:1646-1652. [pmid: 22423254].
Ploux S, Whinnett Z, Lumens J, Denis A, Zemmoura A, De Guillebon M, Ramoul K, Ritter P, Jais P, Clementy J, Haissaguerre M, Bordachar P. Acute hemodynamic response to biventricular pacing in heart failure patients with narrow, moderately, and severely prolonged QRS duration. Heart Rhythm. 2012:1247-1250. [pmid: 22406382].
Zhang Q, Chan YS, Liang YJ, Fang F, Lam YY, Chan CP, Lee AP, Chan KC, Wu EB, Yu CM. Comparison of left ventricular reverse remodeling induced by cardiac contractility modulation and cardiac resynchronization therapy in heart failure patients with different QRS durations. Int J Cardiol. 2013:889-893. [pmid: 22330007].
Bank AJ, Burns KV, Gage RM, Vatterott DB, Adler SW, Sajady M, Rohde D, Parah JS, Anand I, Yong P, Seth M, Kubo SH. Cardiac resynchronization therapy in the real world: comparison with the COMPANION study. J Card Fail. 2012:153-158. [pmid: 22300784].
Pugliese M, Minardi G, Vitali A, Natale E, De Girolamo P, Zampi G, Leggio M, Chiarelli A, Pappalardo A, Avella A, Laurenzi F, Fera MS. Influence of myocardial viability on responsiveness to cardiac resynchronization in ischemic dilated cardiomyopathy: a prospective observational cohort study. Anadolu Kardiyol Derg. 2012:132-141. [pmid: 22281793].
Aksoy H, Okutucu S, Aytemir K, Kaya EB, Evranos B, Kabakci G, Tokgozoglu L, Ozkutlu H, Oto A. Baseline aortic pre-ejection interval predicts reverse remodeling and clinical improvement after cardiac resynchronization therapy. Cardiol J. 2011:639-647. [pmid: 22113751].
Perrotta L, Ricciardi G, Pieragnoli P, Chiostri M, Pontecorboli G, De Santo T, Bellocci F, Vitulano N, Emdin M, Mascioli G, Ricceri I, Porciani MC, Michelucci A, Padeletti L. Application of the Seattle Heart Failure Model in patients on cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2012:88-94. [pmid: 22054166].
Ciampi Q, Pratali L, Citro R, Villari B, Picano E, Sicari R. Additive value of severe diastolic dysfunction and contractile reserve in the identification of responders to cardiac resynchronization therapy. Eur J Heart Fail. 2011:1323-1330. [pmid: 22037388].
Grosu A, Senni M, Iacovoni A, Gori M, Cantu F, Bisetti S, De Santo T, De Luca A, Gavazzi A. CArdiac resynchronization in combination with beta blocker treatment in advanced chronic heart failure (CARIBE-HF): the results of the CARIBE-HF study. Acta Cardiol. 2011:573-580. [pmid: 22032050].
Edner M, Ring M, Henriksson P. Pre-implant right ventricular function might be an important predictor of the response to cardiac resynchronization therapy. Cardiovasc Ultrasound. 2011:28. [pmid: 22029550].
Szulik M, Stabryla-Deska J, Boidol J, Lenarczyk R, Kalarus Z, Kukulski T. Echocardiography-based qualification and response assessment to cardiac resynchronisation therapy in patients with chronic heart failure. The matrix metalloproteinase-9 substudy. Kardiol Pol. 2011:1043-1051. [pmid: 22006606].
Carluccio E, Biagioli P, Alunni G, Murrone A, Pantano P, Biscottini E, Zuchi C, Zingarini G, Cavallini C, Ambrosio G. Presence of extensive LV remodeling limits the benefits of CRT in patients with intraventricular dyssynchrony. JACC Cardiovasc Imaging. 2011:1067-1076. [pmid: 21999865].
Rickard J, Brennan DM, Martin DO, Hsich E, Tang WH, Lindsay BD, Starling RC, Wilkoff BL, Grimm RA. The impact of left ventricular size on response to cardiac resynchronization therapy. Am Heart J. 2011:646-653. [pmid: 21982656].
Blaschke F, Knaus T, Celebi O, Krebs A, Nitardy A, Habedank D, Dietz R, Stockburger M. Ventricular tachycardia or ventricular fibrillation occurs less often in patients with left bundle branch block and combined resynchronization and defibrillators than in patients with narrow QRS and conventional defibrillators. Europace. 2012:224-229. [pmid: 21946820].
Rickard J, Bassiouny M, Cronin EM, Martin DO, Varma N, Niebauer MJ, Tchou PJ, Tang WH, Wilkoff BL. Predictors of response to cardiac resynchronization therapy in patients with a non-left bundle branch block morphology. Am J Cardiol. 2011:1576-1580. [pmid: 21890086].
Lenarczyk R, Wozniak A, Kowalski O, Sokal A, Pruszkowska-Skrzep P, Sredniawa B, Szulik M, Zielinska T, Kukulski T, Stabryla J, Mazurek M, Bialkowski J, Kalarus Z. Effect of cardiac resynchronization on gradient reduction in patients with obstructive hypertrophic cardiomyopathy: preliminary study. Pacing Clin Electrophysiol. 2011:1544-1552. [pmid: 21834852].
Verna E, Ghiringhelli S, Scotti S, Caravati F. Evaluation of baseline contractile reserve vs dyssynchrony as a predictor of functional improvement and long term outcome after resynchronization pacing therapy: a radionuclide stress study. J Nucl Cardiol. 2012:53-62. [pmid: 21769704].
Hotta VT, Martinelli Filho M, Mady C, Mathias W Jr, Vieira ML. Comparison between 2D and 3D echocardiography in the evaluation of reverse remodeling after CRT. Arq Bras Cardiol. 2011:111-121. [pmid: 21691680].
Lousinha A, Oliveira MM, Feliciano J, Galrinho A, Branco LM, Cunha PS, Hamad H, Ramos R, Abreu J, Leal A, Santos S, Soares R, da Silva MN, Ferreira RC. Benefits of cardiac resynchronization therapy in &quot;very dilated cardiomyopathy&quot;. Rev Port Cardiol. 2011:283-294. [pmid: 21638987].
Mooyaart EA, Marsan NA, van Bommel RJ, Thijssen J, Borleffs CJ, Delgado V, van der Wall EE, Schalij MJ, Bax JJ. Comparison of long-term survival of men versus women with heart failure treated with cardiac resynchronization therapy. Am J Cardiol. 2011:63-68. [pmid: 21529733].
Prochnau D, Kuehnert H, Heinke M, Figulla HR, Surber R. Left ventricular lead position and nonspecific conduction delay are predictors of mortality in patients during cardiac resynchronization therapy. Can J Cardiol. 2011:363-368. [pmid: 21507601].
Enomoto K, Yamabe H, Toyama K, Matsuzawa Y, Yamamuro M, Uemura T, Morihisa K, Iwashita S, Kaikita K, Sugiyama S, Ogawa H. Improvement effect on endothelial function in patients with congestive heart failure treated with cardiac resynchronization therapy. J Cardiol. 2011:69-73. [pmid: 21493043].
Muellerleile K, Baholli L, Groth M, Koopmann K, Barmeyer A, Gosau N, Ventura R, Rostock T, Koester R, Adam G, Willems S, Lund G. Quantification of mechanical ventricular dyssynchrony: direct comparison of velocity-encoded and cine magnetic resonance imaging. Rofo. 2011:554-560. [pmid: 21487982].
Kalogeropoulos A, Savoye LP, Georgiopoulou V, Raj L, Lloyd MS, Chiladakis J, Lerakis S, Alexopoulos D, Butler J. Long-term response of the left ventricle to cardiac resynchronization therapy: insights from standard and strain echocardiography. Congest Heart Fail. 2011:71-79. [pmid: 21449995].
Pires LA, Ghio S, Chung ES, Tavazzi L, Abraham WT, Gerritse B. Relationship between acute improvement in left ventricular function to 6-month outcomes after cardiac resynchronization therapy in patients with chronic heart failure. Congest Heart Fail. 2011:65-70. [pmid: 21449994].
Wilinski J, Czarnecka D, Wojciechowska W, Kloch-Badelek M, Jastrzebski M, Bacior B, Sondej T, Kusak P, Przybyla A, Kawecka-Jaszcz K. Clinical and classic echocardiographic features of patients with, and without, left ventricle reverse remodeling following the introduction of cardiac resynchronization therapy. Cardiol J. 2011:157-164. [pmid: 21432822].
Schaer BA, Osswald S, Di Valentino M, Soliman OI, Sticherling C, ten Cate FJ, Jordaens L, Theuns DA. Close connection between improvement in left ventricular function by cardiac resynchronization therapy and the incidence of arrhythmias in cardiac resynchronization therapy-defibrillator patients. Eur J Heart Fail. 2010:1325-1332. [pmid: 20923856].
Sedlacek K, Burianova L, Mlcochova H, Peichl P, Marek T, Kautzner J. Isolated left ventricular pacing results in worse long-term clinical outcome when compared with biventricular pacing: a single-centre randomized study. Europace. 2010:1762-1768. [pmid: 20729533].
D'Andrea A, Scarafile R, Riegler L, Salerno G, Gravino R, Cocchia R, Castaldo F, Allocca F, Limongelli G, Di Salvo G, Cuomo S, Pacileo G, Caso P, Russo MG, Calabro R. Right atrial size and deformation in patients with dilated cardiomyopathy undergoing cardiac resynchronization therapy. Eur J Heart Fail. 2009:1169-1177. [pmid: 19926601].
Adlbrecht C, Hulsmann M, Gwechenberger M, Strunk G, Khazen C, Wiesbauer F, Elhenicky M, Neuhold S, Binder T, Maurer G, Lang IM, Pacher R. Outcome after device implantation in chronic heart failure is dependent on concomitant medical treatment. Eur J Clin Invest. 2009:1073-1081. [pmid: 19843157].
Bonakdar HR, Jorat MV, Fazelifar AF, Alizadeh A, Givtaj N, Sameie N, Sadeghpour A, Haghjoo M. Prediction of response to cardiac resynchronization therapy using simple electrocardiographic and echocardiographic tools. Europace. 2009:1330-1337. [pmid: 19797149].
Wilinski J, Czarnecka D, Wojciechowska W, Kloch-Badelek M, Jastrzebski M, Bacior B, Kwiecien-Sobstel A, Kawecka-Jaszcz K. Different response rates to cardiac resynchronization therapy (CRT) according to the applied definition. Przegl Lek. 2009:130-133. [pmid: 19689037].
Donal E, Thibault H, Bergerot C, Leroux PY, Cannesson M, Thivolet S, Barthelet M, Rivard L, Chevalier P, Ovize M, Daubert JC, Leclerq C, Mabo P, Derumeaux G. Right ventricular pump function after cardiac resynchronization therapy: a strain imaging study. Arch Cardiovasc Dis. 2008:475-484. [pmid: 18848690].
Menardi E, Vado A, Rossetti G, Racca E, Conte E, Deorsola A, Bobbio M, Feola M. Cardiac resynchronization therapy modifies the neurohormonal profile, hemodynamic and functional capacity in heart failure patients. Arch Med Res. 2008:702-708. [pmid: 18760200].
Santos KR, Adragao P, Cavaco D, Morgado FB, Candeias R, Lima S, Silva JA. Diaphragmatic myopotential oversensing in pacemaker-dependent patients with CRT-D devices. Europace. 2008:1381-1386. [pmid: 18757865].
Tolosana JM, Hernandez Madrid A, Brugada J, Sitges M, Garcia Bolao I, Fernandez Lozano I, Martinez Ferrer J, Quesada A, Macias A, Marin W, Escudier JM, Gomez AA, Gimenez Alcala M, Tamborero D, Berruezo A, Mont L. Comparison of benefits and mortality in cardiac resynchronization therapy in patients with atrial fibrillation versus patients in sinus rhythm (Results of the Spanish Atrial Fibrillation and Resynchronization. Am J Cardiol. 2008:444-449. [pmid: 18678303].
Cleland J, Freemantle N, Ghio S, Fruhwald F, Shankar A, Marijanowski M, Verboven Y, Tavazzi L. Predicting the long-term effects of cardiac resynchronization therapy on mortality from baseline variables and the early response a report from the CARE-HF (Cardiac Resynchronization in Heart Failure) Trial. J Am Coll Cardiol. 2008:438-445. [pmid: 18672164].
Soliman OI, van Dalen BM, Theuns DA, ten Cate FJ, Nemes A, Jordaens LJ, Geleijnse ML. The ischemic etiology of heart failure in diabetics limits reverse left ventricular remodeling after cardiac resynchronization therapy. J Diabetes Complications. 2009:365-370. [pmid: 18572420].
Lellouche N, De Diego C, Vaseghi M, Buch E, Cesario DA, Mahajan A, Wiener I, Fonarow GC, Boyle NG, Shivkumar K. Cardiac resynchronization therapy response is associated with shorter duration of atrial fibrillation. Pacing Clin Electrophysiol. 2007:1363-1368. [pmid: 17976100].
Lin G, Rea RF, Hammill SC, Hayes DL, Brady PA. Effect of cardiac resynchronisation therapy on occurrence of ventricular arrhythmia in patients with implantable cardioverter defibrillators undergoing upgrade to cardiac resynchronisation therapy devices. Heart. 2008:186-190. [pmid: 17761506].
Laurenzi F, Achilli A, Avella A, Peraldo C, Orazi S, Perego GB, Cesario A, Valsecchi S, De Santo T, Puglisi A, Tondo C. Biventricular upgrading in patients with conventional pacing system and congestive heart failure: results and response predictors. Pacing Clin Electrophysiol. 2007:1096-1104. [pmid: 17725752].
Cha YM, Rea RF, Wang M, Shen WK, Asirvatham SJ, Friedman PA, Munger TM, Espinosa RE, Hodge DO, Hayes DL, Redfield MM. Response to cardiac resynchronization therapy predicts survival in heart failure: a single-center experience. J Cardiovasc Electrophysiol. 2007:1015-1019. [pmid: 17711439].
Stanchina ML, Ellison K, Malhotra A, Anderson M, Kirk M, Benser ME, Tosi C, Carlisle C, Millman RP, Buxton A. The impact of cardiac resynchronization therapy on obstructive sleep apnea in heart failure patients: a pilot study. Chest. 2007:433-439. [pmid: 17573498].
Rao BH, Kalavakolanu S, Chandrasekar K, Sastry BK, Narasimhan C. Cardiac resynchronization therapy in hemodynamically unstable heart failure patients. Indian Heart J. 2007:185-187. [pmid: 19122255].
Delnoy PP, Ottervanger JP, Luttikhuis HO, Nicastia DM, Elvan A, Misier AR, Beukema W. Sustained benefit of cardiac resynchronization therapy. J Cardiovasc Electrophysiol. 2007:298-302. [pmid: 17284263].
Achilli A, Peraldo C, Sassara M, Orazi S, Bianchi S, Laurenzi F, Donati R, Perego GB, Spampinato A, Valsecchi S, Denaro A, Puglisi A. Prediction of response to cardiac resynchronization therapy: the selection of candidates for CRT (SCART) study. Pacing Clin Electrophysiol. 2006:S11-S19. [pmid: 17169127].
Ypenburg C, van Erven L, Bleeker GB, Bax JJ, Bootsma M, Wijffels MC, van der Wall EE, Schalij MJ. Benefit of combined resynchronization and defibrillator therapy in heart failure patients with and without ventricular arrhythmias. J Am Coll Cardiol. 2006:464-470. [pmid: 16875970].
Konstantino Y, Iakobishvili Z, Arad O, Ben-Gal T, Kusniec J, Mazur A, Porter A, Strasberg B, Battler A, Hasdai D. Urgent cardiac resynchronization therapy in patients with decompensated chronic heart failure receiving inotropic therapy. A case series. Cardiology. 2006:59-62. [pmid: 16612071].
James KB, Militello M, Barbara G, Wilkoff BL. Biventricular pacing for heart failure patients on inotropic support: a review of 38 consecutive cases. Tex Heart Inst J. 2006:19-22. [pmid: 16572863].
Porciani MC, Macioce R, Demarchi G, Chiostri M, Musilli N, Cappelli F, Lilli A, Ricciardi G, Padeletti L. Effects of cardiac resynchronization therapy on the mechanisms underlying functional mitral regurgitation in congestive heart failure. Eur J Echocardiogr. 2006:31-39. [pmid: 16378918].
Schlosshan D, Barker D, Pepper C, Williams G, Morley C, Tan LB. CRT improves the exercise capacity and functional reserve of the failing heart through enhancing the cardiac flow- and pressure-generating capacity. Eur J Heart Fail. 2006:515-521. [pmid: 16377239].
Ritter O, Koller ML, Fey B, Seidel B, Krein A, Langenfeld H, Bauer WR. Progression of heart failure in right univentricular pacing compared to biventricular pacing. Int J Cardiol. 2006:359-365. [pmid: 16297471].
Fantoni C, Raffa S, Regoli F, Giraldi F, La Rovere MT, Prentice J, Pastori F, Fratini S, Salerno-Uriarte JA, Klein HU, Auricchio A. Cardiac resynchronization therapy improves heart rate profile and heart rate variability of patients with moderate to severe heart failure. J Am Coll Cardiol. 2005:1875-1882. [pmid: 16286175].
Skobel EC, Sinha AM, Norra C, Randerath W, Breithardt OA, Breuer C, Hanrath P, Stellbrink C. Effect of cardiac resynchronization therapy on sleep quality, quality of life, and symptomatic depression in patients with chronic heart failure and Cheyne-Stokes respiration. Sleep Breath. 2005:159-166. [pmid: 16283229].
Malfatto G, Facchini M, Branzi G, Brambilla R, Fratianni G, Tortorici E, Balla E, Perego GB. Reverse ventricular remodeling and improved functional capacity after ventricular resynchronization in advanced heart failure. Ital Heart J. 2005:578-583. [pmid: 16274020].
Najem B, Preumont N, Unger P, Jansens JL, Houssiere A, Ciarka A, Stoupel E, Degaute JP, van de Borne P. Sympathetic nerve activity after thoracoscopic cardiac resynchronization therapy in congestive heart failure. J Card Fail. 2005:529-533. [pmid: 16198249].
Kies P, Leclercq C, Bleeker GB, Crocq C, Molhoek SG, Poulain C, van Erven L, Bootsma M, Zeppenfeld K, van der Wall EE, Daubert JC, Schalij MJ, Bax JJ. Cardiac resynchronisation therapy in chronic atrial fibrillation: impact on left atrial size and reversal to sinus rhythm. Heart. 2006:490-494. [pmid: 16159986].
Molhoek SG, Bax JJ, Bleeker GB, Holman ER, Van Erven L, Bootsma M, Boersma E, Steendijk P, Van Der Wall EE, Schalij MJ. Long-term follow-up of cardiac resynchronization therapy in patients with end-stage heart failure. J Cardiovasc Electrophysiol. 2005:701-707. [pmid: 16050826].
Ferro A, Duilio C, Santomauro M, Salvatore M, Cuocolo A. Haemodynamic effects of dual-chamber pacing versus ventricular pacing during a walk test in patients with depressed or normal left ventricular function. Eur J Nucl Med Mol Imaging. 2005:1075-1080. [pmid: 15891919].
Bernheim A, Ammann P, Sticherling C, Burger P, Schaer B, Brunner-La Rocca HP, Eckstein J, Kiencke S, Kaiser C, Linka A, Buser P, Pfisterer M, Osswald S. Right atrial pacing impairs cardiac function during resynchronization therapy: acute effects of DDD pacing compared to VDD pacing. J Am Coll Cardiol. 2005:1482-1487. [pmid: 15862423].
Davis DR, Krahn AD, Tang AS, Lemery R, Green MS, Gollob M, Yee R, Skanes AC, Klein GJ, Birnie DH. Long-term outcome of cardiac resynchronization therapy in patients with severe congestive heart failure. Can J Cardiol. 2005:413-417. [pmid: 15861258].
Braunschweig F, Mortensen PT, Gras D, Reiser W, Lawo T, Mansour H, Sogaard P, Stegemann B, Bruns HJ, Linde C. Monitoring of physical activity and heart rate variability in patients with chronic heart failure using cardiac resynchronization devices. Am J Cardiol. 2005:1104-1107. [pmid: 15842984].
Aranda JM Jr, Woo GW, Conti JB, Schofield RS, Conti CR, Hill JA. Use of cardiac resynchronization therapy to optimize beta-blocker therapy in patients with heart failure and prolonged QRS duration. Am J Cardiol. 2005:889-891. [pmid: 15781026].
Waggoner AD, Faddis MN, Gleva MJ, De Las Fuentes L, Osborn J, Heuerman S, Davila-Roman VG. Cardiac resynchronization therapy acutely improves diastolic function. J Am Soc Echocardiogr. 2005:216-220. [pmid: 15746709].
De Cock CC, Van Campen LM, Jessurun ER, Allaart CA, Vos DS, Visser CA. Long-term follow-up of patients with refractory heart failure and myocardial ischemia treated with cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2005:S8-S10. [pmid: 15683533].
Funck RC, Koelsch S, Waldhans S, Prinz H, Grimm W, Moosdorf R, Maisch B. Marked improvement in left ventricular function and significant reverse left ventricular remodeling within 3 months of cardiac resynchronization therapy in patients with dilated cardiomyopathy. Pacing Clin Electrophysiol. 2005:S5-S7. [pmid: 15683524].
Boriani G, Fallani F, Martignani C, Biffi M, Saporito D, Greco C, Ziacchi M, Levorato M, Pontone G, Valzania C, Diemberger I, Franchi R, Branzi A. Cardiac resynchronization therapy: effects on left and right ventricular ejection fraction during exercise. Pacing Clin Electrophysiol. 2005:S11-S14. [pmid: 15683474].
Molhoek SG, Bax JJ, Bleeker GB, Boersma E, van Erven L, Steendijk P, van der Wall EE, Schalij MJ. Comparison of response to cardiac resynchronization therapy in patients with sinus rhythm versus chronic atrial fibrillation. Am J Cardiol. 2004:1506-1509. [pmid: 15589005].
Lancellotti P, Melon P, Sakalihasan N, Waleffe A, Dubois C, Bertholet M, Pierard LA. Effect of cardiac resynchronization therapy on functional mitral regurgitation in heart failure. Am J Cardiol. 2004:1462-1465. [pmid: 15566929].
da Silva Menezes A. Outcome of right ventricular bifocal pacing in patients with permanent atrial fibrillation and severe dilated cardiomiopathy due to Chagas disease: three years of follow-up. J Interv Card Electrophysiol. 2004:193-198. [pmid: 15548885].
Dixon LJ, Murtagh JG, Richardson SG, Chew EW. Reduction in hospitalization rates following cardiac resynchronisation therapy in cardiac failure: experience from a single centre. Europace. 2004:586-589. [pmid: 15519262].
Leclercq C, Gras D, Tang A, Alonso C, Thomas-Revault d'Allones F, Mabo P. Comparative effects of ventricular resynchronization therapy in heart failure patients with or without coronary artery disease. Ann Cardiol Angeiol (Paris). 2004:171-176. [pmid: 15369312].
Ammann P, Kiencke S, Schaer B, Cron TA, Sticherling C, Huldi C, Linka A, Buser P, Pfisterer M, Osswald S. Cardiac resynchronization in severe heart failure and left bundle branch block: a single center experience. Swiss Med Wkly. 2004:277-282. [pmid: 15243848].
Bonanno C, Ometto R, Pasinato S, Finocchi G, La Vecchia L, Fontanelli A. Effects of cardiac resynchronization therapy on disease progression in patients with congestive heart failure. Ital Heart J. 2004:364-370. [pmid: 15185900].
Takemoto M, Sakamoto M, Kawagoe J, Goto K, Baba H, Noma M, Origuchi H, Yoshimura H, Sese A, Yamamoto H. Effect of biventricular pacing therapy in patients with dilated cardiomyopathy with severe congestive heart failure. Jpn J Thorac Cardiovasc Surg. 2004:175-180. [pmid: 15141704].
Achilli A, Sassara M, Ficili S, Pontillo D, Achilli P, Alessi C, De Spirito S, Guerra R, Patruno N, Serra F. Long-term effectiveness of cardiac resynchronization therapy in patients with refractory heart failure and &quot;narrow&quot; QRS. J Am Coll Cardiol. 2003:2117-2124. [pmid: 14680737].
Greenberg JM, Leon AR, Book WM, Hott BJ, DeLurgio DB, Langberg JJ, Smith AL. Benefits of cardiac resynchronization therapy in outpatients with indicators for heart transplantation. J Heart Lung Transplant. 2003:1134-1140. [pmid: 14550823].
Chan KL, Tang AS, Achilli A, Sassara M, Bocchiardo M, Gaita F, Cavaglia S, Hilpisch K, Hill MR, Gras D. Functional and echocardiographic improvement following multisite biventricular pacing for congestive heart failure. Can J Cardiol. 2003:387-390. [pmid: 12704484].
Ohkusu Y, Takahashi N, Ishikawa T, Sumita S, Kobayashi T, Matsushita K, Yamakawa Y, Uchino K, Kimura K, Inoue T, Umemura S. Effect of biventricular pacing on myocardial glucose metabolism in patients with heart failure using fluoro-18-deoxyglucose positron emission tomography. Pacing Clin Electrophysiol. 2003:144-147. [pmid: 12687800].
Cazeau S, Bordachar P, Jauvert G, Lazarus A, Alonso C, Vandrell MC, Mugica J, Ritter P. Echocardiographic modeling of cardiac dyssynchrony before and during multisite stimulation: a prospective study. Pacing Clin Electrophysiol. 2003:137-143. [pmid: 12687799].
Mascioli G, Curnis A, Bontempi L, Dei Cas L. Biventricular pacing for patients with severe congestive heart failure: a single center experience. Ital Heart J. 2002:598-602. [pmid: 12478818].
Lehmann A, Lang J, Thaler E, Zeitler C, Weisse U, Boldt J. Considerations in patients undergoing implantation of a biventricular pacemaker. J Cardiothorac Vasc Anesth. 2002:175-179. [pmid: 11957166].
Leon AR, Greenberg JM, Kanuru N, Baker CM, Mera FV, Smith AL, Langberg JJ, DeLurgio DB. Cardiac resynchronization in patients with congestive heart failure and chronic atrial fibrillation: effect of upgrading to biventricular pacing after chronic right ventricular pacing. J Am Coll Cardiol. 2002:1258-1263. [pmid: 11955841].
Saxon LA, De Marco T, Schafer J, Chatterjee K, Kumar UN, Foster E. Effects of long-term biventricular stimulation for resynchronization on echocardiographic measures of remodeling. Circulation. 2002:1304-1310. [pmid: 11901040].
Yu CM, Chau E, Sanderson JE, Fan K, Tang MO, Fung WH, Lin H, Kong SL, Lam YM, Hill MR, Lau CP. Tissue Doppler echocardiographic evidence of reverse remodeling and improved synchronicity by simultaneously delaying regional contraction after biventricular pacing therapy in heart failure. Circulation. 2002:438-445. [pmid: 11815425].
Auricchio A, Kloss M, Trautmann SI, Rodner S, Klein H. Exercise performance following cardiac resynchronization therapy in patients with heart failure and ventricular conduction delay. Am J Cardiol. 2002:198-203. [pmid: 11792342].
Kostic T, Perisic Z, Milic D, Mitov V, Koracevic G, Salinger-Martinovic S, Apostolovic S, Zivkovic M, Stanojevic D, Golubovic M, Markovic S. Long-term benefits of cardiac resynchronization therapy in heart failure patients. HealthMED. 2012:4113-4119.
Chen S, Yin Y, Krucoff MW. Effect of cardiac resynchronization therapy and implantable cardioverter defibrillator on quality of life in patients with heart failure: A meta-analysis. Europace. 2012:1602-1607. [pmid: 23104857].
Leclercq C, Cazeau S, Ritter P, Alonso C, Gras D, Mabo P, Lazarus A, Daubert JC. A pilot experience with permanent biventricular pacing to treat advanced heart failure. Am. Heart. J. 2000:862-870. [pmid: 11099989].
Davoodi G, Bagheri A, Yamini-Sharif A, Boroumand M, Saroukhani S, Sahebjam M. Evaluation of in-hospital NT-proBNP changes in heart failure patients to identify the six-month clinical response following cardiac resynchronization therapy. Acta Med. Iran. 2014:15-23. [pmid: 24658981].
Ito T, Kizawa S, Nogi S, Shimamoto S, Yokoyama K, Ishizaka N. Association between presystolic ventricular flash and left ventricular functional recovery after cardiac resynchronization therapy. Echocardiography. 2014:149-154. [pmid: 23906029].
Hurlimann D, Schmidt S, Seifert B, Saguner AM, Hindricks G, Luscher TF, Ruschitzka F, Steffel J. Outcome of super-responders to cardiac resynchronization therapy defined by endpoint-derived parameters of left ventricular remodeling: a two-center retrospective study. Clin Res Cardiol. 2014.
Bilchick KC, Stukenborg GJ. Comparative Effectiveness of Cardiac Resynchronization Therapy in Combination With Implantable Defibrillator in Patients With Heart Failure and Wide QRS Duration. Am J Cardiol. 2014.
Khazanie P, Hammill BG, Qualls LG, Fonarow GC, Hammill SC, Heidenreich PA, Al-Khatib SM, Piccini JP, Masoudi FA, Peterson PN, Curtis JP, Hernandez AF, Curtis LH. Clinical Effectiveness of Cardiac Resynchronization Therapy vs Medical Therapy Alone Among Patients With Heart Failure: An Analysis of the ICD and ADHERE National Registries. Circ Heart Fail. 2014.
Agacdiken Agir A, Celikyurt U, Sahin T, Yilmaz I, Karauzum K, Bozyel S, Ural D, Vural A. What is the lowest value of left ventricular baseline ejection fraction that predicts response to cardiac resynchronization therapy?. Med Sci Monit. 2014:1641-1646. [pmid: 25218410].
Gage RM, Burns KV, Bank AJ. Echocardiographic and clinical response to cardiac resynchronization therapy in heart failure patients with and without previous right ventricular pacing. Eur J Heart Fail. 2014.
Yang XW, Hua W, Wang J, Liu ZM, Ding LG, Chen KP, Zhang S. Regression of Fragmented QRS Complex: A Marker of Electrical Reverse Remodeling in Cardiac Resynchronization Therapy. Ann Noninvasive Electrocardiol. 2014.
Bose A, Upadhyay GA, Kandala J, Heist EK, Mela T, Parks KA, Singh JP. Does Prior Valve Surgery Change Outcome in Patients Treated with Cardiac Resynchronization Therapy?. J Cardiovasc Electrophysiol. 2014.
Bogdan S, Klempfner R, Sabbag A, Luria D, Gurevitz O, Bar-Lev D, Lipchenca I, Nof E, Kuperstein R, Goldenberg I, Eldar M, Glikson M, Beinart R. Functional Response to Cardiac Resynchronization Therapy in Patients with Renal Dysfunction and Subsequent Long-Term Mortality. J Cardiovasc Electrophysiol. 2014.
Sokal A, Jedrzejczyk E, Lenarczyk R, Pluta S, Kowalski O, Pruszkowska P, Mazurek M, Swiatkowski A, Kalarus Z. Efficacy of cardiac resynchronisation therapy in the treatment of end-stage inotrope-dependent heart failure patients. Kardiol Pol. 2014:777-782. [pmid: 24846358].
Roger S, Schneider R, Rudic B, Liebe V, Stach K, Schimpf R, Borggrefe M, Kuschyk J. Cardiac contractility modulation: first experience in heart failure patients with reduced ejection fraction and permanent atrial fibrillation. Europace. 2014:1205-1209. [pmid: 24706089].

## Other

Thoren E, Kesek M, Jideus L. The effect of concomitant cardiac resynchronization therapy on quality of life in patients with heart failure undergoing cardiac surgery. Open Cardiovasc Med J. 2014:18-22. [pmid: 24665351].
Antonio N, Soares A, Carvalheiro T, Fernandes R, Paiva A, Ventura M, Cristovao J, Elvas L, Goncalves L, Providencia LA, Fontes Ribeiro C, Mariano Pego G. Circulating Endothelial Progenitor Cells as a Predictor of Response to Cardiac Resynchronization Therapy: The Missing Piece of the Puzzle?. Pacing Clin Electrophysiol. 2014.
Ford J, Sears S, Ramza B, Reynolds DW, Nguyen P, Fedewa M, House J, Kennedy P, Thompson R, Murray C. The Registry Evaluating Functional Outcomes of Resynchronization Management (REFORM): quality of life and psychological functioning in patients receiving cardiac resynchronization therapy. J Cardiovasc Electrophysiol. 2014:43-51. [pmid: 24102945].
O'Donnell D, Lin T, Swale M, Rae P, Flannery D, Srivastava PM. Long-term clinical response to cardiac resynchronisation therapy under a multidisciplinary model. Intern Med J. 2013:1216-1223. [pmid: 24015775].
Linde C, Daubert C, Abraham WT, St John Sutton M, Ghio S, Hassager C, Herre JM, Bergemann TL, Gold MR. Impact of ejection fraction on the clinical response to cardiac resynchronization therapy in mild heart failure. Circ Heart Fail. 2013:1180-1189. [pmid: 24014828].
Ruschitzka F, Abraham WT, Singh JP, Bax JJ, Borer JS, Brugada J, Dickstein K, Ford I, Gorcsan J 3rd, Gras D, Krum H, Sogaard P, Holzmeister J. Cardiac-resynchronization therapy in heart failure with a narrow QRS complex. N Engl J Med. 2013:1395-1405. [pmid: 23998714].
Peterson PN, Greiner MA, Qualls LG, Al-Khatib SM, Curtis JP, Fonarow GC, Hammill SC, Heidenreich PA, Hammill BG, Piccini JP, Hernandez AF, Curtis LH, Masoudi FA. QRS duration, bundle-branch block morphology, and outcomes among older patients with heart failure receiving cardiac resynchronization therapy. JAMA. 2013:617-626. [pmid: 23942680].
Iwano H, Yamada S, Watanabe M, Mitsuyama H, Mizukami K, Nishino H, Yokoyama S, Kaga S, Okada K, Nishida M, Yokoshiki H, Mikami T, Tsutsui H. Strain rate dispersion index can predict changes in left ventricular volume and adverse cardiac events following cardiac resynchronization therapy. Circ J. 2013:2757-2765. [pmid: 23924889].
Yamamoto T, Shimano M, Inden Y, Miyata S, Inoue Y, Yoshida N, Tsuji Y, Hirai M, Murohara T. Cystatin C as a predictor of mortality and cardiovascular morbidity after cardiac resynchronization therapy. Circ J. 2013:2751-2756. [pmid: 23912790].
Brenyo A, Barsheshet A, Rao M, Huang DT, Zareba W, McNitt S, Hall WJ, Peterson DR, Solomon SD, Moss AJ, Goldenberg I. Brain natriuretic peptide and cardiac resynchronization therapy in patients with mildly symptomatic heart failure. Circ Heart Fail. 2013:998-1004. [pmid: 23801020].
Mollo R, Cosenza A, Coviello I, Stazi A, Russo G, Villano A, Sestito A, Bencardino G, Lanza GA, Crea F. A novel electrocardiographic predictor of clinical response to cardiac resynchronization therapy. Europace. 2013:1615-1621. [pmid: 23794613].
Ruwald MH, Abu-Zeitone A, Jons C, Ruwald AC, McNitt S, Kutyifa V, Zareba W, Moss AJ. Impact of carvedilol and metoprolol on inappropriate implantable cardioverter-defibrillator therapy: the MADIT-CRT trial (Multicenter Automatic Defibrillator Implantation With Cardiac Resynchronization Therapy). J Am Coll Cardiol. 2013:1343-1350. [pmid: 23770172].
Benfatti RA, Manzano FM, Pontes JC, Dias AE, Duarte JJ, Silva GV, Gomes Junior JF, Gardenal N. Analysis of left ventricular function in patients with heart failure undergoing cardiac resynchronization. Rev Bras Cir Cardiovasc. 2013:69-75. [pmid: 23739935].
Gierula J, Cubbon RM, Jamil HA, Byrom R, Baxter PD, Pavitt S, Gilthorpe MS, Hewison J, Kearney MT, Witte KK. Cardiac resynchronization therapy in pacemaker-dependent patients with left ventricular dysfunction. Europace. 2013:1609-1614. [pmid: 23736807].
Manne M, Rickard J, Varma N, Chung MK, Tchou P. Normalization of left ventricular ejection fraction after cardiac resynchronization therapy also normalizes survival. Pacing Clin Electrophysiol. 2013:970-977. [pmid: 23718783].
Agacdiken A, Celikyurt U, Sahin T, Karauzum K, Vural A, Ural D. Neutrophil-to-lymphocyte ratio predicts response to cardiac resynchronization therapy. Med Sci Monit. 2013:373-377. [pmid: 23686301].
Linde C, Gold MR, Abraham WT, St John Sutton M, Ghio S, Cerkvenik J, Daubert C. Long-term impact of cardiac resynchronization therapy in mild heart failure: 5-year results from the REsynchronization reVErses Remodeling in Systolic left vEntricular dysfunction (REVERSE) study. Eur Heart J. 2013:2592-2599. [pmid: 23641006].
Kutyifa V, Klein HU, Wang PJ, McNitt S, Polonsky B, Zima E, Merkely B, Moss AJ, Zareba W. Clinical significance of ventricular tachyarrhythmias in patients treated with CRT-D. Heart Rhythm. 2013:943-950. [pmid: 23639624].
Biventricular pacing for adults with AV block and heart failure. BMJ. 2013:f2719. [pmid: 23637151].
Bhavnani SP, Pavuluri V, Coleman CI, Guertin D, Yarlagadda RK, Clyne CA, Kluger J. The gender-paradox among patients with implantable cardioverter-defibrillators: a propensity-matched study. Pacing Clin Electrophysiol. 2013:878-884. [pmid: 23614760].
Hernandez Madrid A, Matia Frances R, Moro C, Zamorano J. Cardiac resynchronization therapy: do patient selection and implant practice vary depending on the volume a center handles?. Pacing Clin Electrophysiol. 2013:863-871. [pmid: 23594313].
Muto C, Solimene F, Gallo P, Nastasi M, La Rosa C, Calvanese R, Iengo R, Canciello M, Sangiuolo R, Diemberger I, Ciardiello C, Tuccillo B. A randomized study of cardiac resynchronization therapy defibrillator versus dual-chamber implantable cardioverter-defibrillator in ischemic cardiomyopathy with narrow QRS: the NARROW-CRT study. Circ Arrhythm Electrophysiol. 2013:538-545. [pmid: 23592833].
Angheloiu GO, Saul M, Edelman K, Shah H, Mezu UL, Saba S. Predictors of left ventricular function deterioration in patients with left bundle branch block and ejection fraction &gt;50%. Congest Heart Fail. 2013:E1-E4. [pmid: 23586729].
Damy T, Ghio S, Rigby AS, Hittinger L, Jacobs S, Leyva F, Delgado JF, Daubert JC, Gras D, Tavazzi L, Cleland JG. Interplay between right ventricular function and cardiac resynchronization therapy: an analysis of the CARE-HF trial (Cardiac Resynchronization-Heart Failure). J Am Coll Cardiol. 2013:2153-2160. [pmid: 23541971].
Pan W, Su Y, Zhu W, Shu X, Ge J. Notched QRS complex in lateral leads as a novel predictor of response to cardiac resynchronization therapy. Ann Noninvasive Electrocardiol. 2013:181-187. [pmid: 23530489].
Ruwald MH, Ruwald AC, Jons C, Alexis J, McNitt S, Zareba W, Moss AJ. Effect of metoprolol versus carvedilol on outcomes in MADIT-CRT (multicenter automatic defibrillator implantation trial with cardiac resynchronization therapy). J Am Coll Cardiol. 2013:1518-1526. [pmid: 23500269].
Minamiguchi H, Sakata Y, Ohtani T, Mizote I, Takeda Y, Mizuno H, Okuyama Y, Nakatani S, Fujita M, Watanabe T, Uematsu M, Komuro I. Usefulness of overlapping of the E and A waves of the transmitral flow as a predictor of responders to cardiac resynchronization therapy. Am J Cardiol. 2013:1613-1618. [pmid: 23497774].
Boidol J, Sredniawa B, Kowalski O, Szulik M, Mazurek M, Sokal A, Pruszkowska-Skrzep P, Kukulski T, Kalarus Z, Lenarczyk R. Many response criteria are poor predictors of outcomes after cardiac resynchronization therapy: validation using data from the randomized trial. Europace. 2013:835-844. [pmid: 23487543].
Osmancik P, Herman D, Stros P, Linkova H, Vondrak K, Paskova E. Changes and prognostic impact of apoptotic and inflammatory cytokines in patients treated with cardiac resynchronization therapy. Cardiology. 2013:190-198. [pmid: 23486075].
Vaillant C, Martins RP, Donal E, Leclercq C, Thebault C, Behar N, Mabo P, Daubert JC. Resolution of left bundle branch block-induced cardiomyopathy by cardiac resynchronization therapy. J Am Coll Cardiol. 2013:1089-1095. [pmid: 23352778].
Tomassoni G, Baker J, Corbisiero R, Love C, Martin D, Niazi I, Sheppard R, Worley S, Beau S, Greer GS, Aryana A, Cao M, Harbert N, Zhang S. Postoperative performance of the Quartet(R) left ventricular heart lead. J Cardiovasc Electrophysiol. 2013:449-456. [pmid: 23339555].
Ahsan SY, Saberwal B, Lambiase PD, Chaubey S, Segal OR, Gopalamurugan AB, McCready J, Rogers DP, Lowe MD, Chow AW. An 8-year single-centre experience of cardiac resynchronisation therapy: procedural success, early and late complications, and left ventricular lead performance. Europace. 2013:711-717. [pmid: 23315159].
Xu GJ, Gan TY, Tang BP, Ma YT, Zhang Y, Li JX, Zhang YY, Wang J, Tang Q, Wang CM, Li YD, Zhang JH. Predictive factors and clinical effect of optimized cardiac resynchronization therapy. Exp Ther Med. 2013:355-361. [pmid: 23251298].
Perrotta L, Xhaferi B, Chiostri M, Pieragnoli P, Ricciardi G, Di Biase L, Natale A, Ricceri I, Biria M, Lakkireddy D, Valleggi A, Emdin M, Michelotti F, Mascioli G, Pandozi A, Santini M, Padeletti L. Effects of smoking in patients treated with cardiac resynchronization therapy. Intern Emerg Med. 2014:311-318. [pmid: 23250544].
Hoke U, Thijssen J, van Bommel RJ, van Erven L, van der Velde ET, Holman ER, Schalij MJ, Bax JJ, Delgado V, Marsan NA. Influence of diabetes on left ventricular systolic and diastolic function and on long-term outcome after cardiac resynchronization therapy. Diabetes Care. 2013:985-991. [pmid: 23223348].
Chan YH, Wu LS, Kuo CT, Wang CL, Yeh YH, Ho WJ, Hsu LA. Incremental value of inefficient deformation indices for predicting response to cardiac resynchronization therapy. J Am Soc Echocardiogr. 2013:307-315. [pmid: 23218965].
Oh C, Chang HJ, Sung JM, Kim JY, Yang W, Shim J, Kang SM, Ha J, Rim SJ, Chung N. Prognostic Estimation of Advanced Heart Failure With Low Left Ventricular Ejection Fraction and Wide QRS Interval. Korean Circ J. 2012:659-667. [pmid: 23170093].
Stanciu AE, Vatasescu RG, Stanciu MM, Iorgulescu C, Vasile AI, Dorobantu M. Cardiac resynchronization therapy in patients with chronic heart failure is associated with anti-inflammatory and anti-remodeling effects. Clin Biochem. 2013:230-234. [pmid: 23159290].
Leyva F, Taylor RJ, Foley PW, Umar F, Mulligan LJ, Patel K, Stegemann B, Haddad T, Smith RE, Prasad SK. Left ventricular midwall fibrosis as a predictor of mortality and morbidity after cardiac resynchronization therapy in patients with nonischemic cardiomyopathy. J Am Coll Cardiol. 2012:1659-1667. [pmid: 23021326].
Reithmann C, Herkommer B, Huemmer A, von Hoch F, Fiek M. The risk of delayed atrioventricular and intraventricular conduction block following ablation of bundle branch reentry. Clin Res Cardiol. 2013:145-153. [pmid: 23015015].
Imanishi J, Tanaka H, Matsumoto K, Tatsumi K, Miyoshi T, Hiraishi M, Kaneko A, Ryo K, Fukuda Y, Yoshida A, Yokoyama M, Kawai H, Hirata K. Utility of combined assessment of baseline dyssynchrony and its acute improvement to predict long-term outcomes after cardiac resynchronization therapy. Am J Cardiol. 2012:1814-1819. [pmid: 22981265].
Celikyurt U, Agacdiken A, Sahin T, Al N, Vural A, Ural D. Relationship between fragmented QRS and response to cardiac resynchronization therapy. J Interv Card Electrophysiol. 2012:337-342. discussion 342. [pmid: 22926204].
Park MY, Altman RK, Orencole M, Kumar P, Parks KA, Heist KE, Singh JP, Picard MH. Characteristics of responders to cardiac resynchronization therapy: the impact of echocardiographic left ventricular volume. Clin Cardiol. 2012:777-780. [pmid: 22886700].
Kaneshiro T, Suzuki H, Yamada S, Kamiyama Y, Saitoh S, Takeishi Y. Intrathoracic impedance changes reflect reverse left ventricular remodeling in response to cardiac resynchronization therapy in chronic heart failure patients. Int Heart J. 2012:249-252. [pmid: 22878804].
Praus R, Haman L, Tauchman M, Blaha V, Parizek P. Cardiac resynchronization therapy in clinical responders: right ventricular echocardiographic changes at mid-term follow-up. Acta Cardiol. 2012:311-316. [pmid: 22870739].
Kyriacou A, Whinnett ZI, Sen S, Pabari PA, Wright I, Cornelussen R, Lefroy D, Davies DW, Peters NS, Kanagaratnam P, Mayet J, Hughes AD, Francis DP, Davies JE. Improvement in coronary blood flow velocity with acute biventricular pacing is predominantly due to an increase in a diastolic backward-travelling decompression (suction) wave. Circulation. 2012:1334-1344. [pmid: 22855569].
Mandal S, Pande A, Mandal D, Kumar A, Sarkar A, Kahali D, Mazumdar B, Panja M. Permanent pacemaker-related upper extremity deep vein thrombosis: a series of 20 cases. Pacing Clin Electrophysiol. 2012:1194-1198. [pmid: 22816726].
Bogaard MD, Hesselink T, Meine M, Loh P, Hauer RN, Cramer MJ, Doevendans PA, Tuinenburg AE. The ECG in cardiac resynchronization therapy: influence of left and right ventricular preactivation and relation to acute response. J Cardiovasc Electrophysiol. 2012:1237-1245. [pmid: 22734629].
Rodriguez DJ, Afzal A, Evonich R, Haines DE. The prevalence of methicillin resistant organisms among pacemaker and defibrillator implant recipients. Am J Cardiovasc Dis. 2012:116-122. [pmid: 22720201].
Kloch Badelek M, Klocek M, Czarnecka D, Wojciechowska W, Wilinski J, Kawecka Jaszcz K. Impact of cardiac resynchronisation therapy on physical ability and quality of life in patients with chronic heart failure. Kardiol Pol. 2012:581-588. [pmid: 22718376].
Celikyurt U, Agacdiken A, Sahin T, Kozdag G, Vural A, Ural D. Association between red blood cell distribution width and response to cardiac resynchronization therapy. J Interv Card Electrophysiol. 2012:215-218. [pmid: 22688952].
Valzania C, Gadler F, Boriani G, Eriksson MJ. Changes in global longitudinal strain during rest and exercise in patients treated with cardiac resynchronization therapy. Clin Physiol Funct Imaging. 2012:310-316. [pmid: 22681609].
Shah RV, Altman RK, Park MY, Zilinski J, Leyton-Mange J, Orencole M, Picard MH, Barrett CD, Heist EK, Upadhyay G, Das R, Singh JP, Das S. Usefulness of hemoglobin A(1c) to predict outcome after cardiac resynchronization therapy in patients with diabetes mellitus and heart failure. Am J Cardiol. 2012:683-688. [pmid: 22632827].
Kreuz J, Horlbeck F, Linhart M, Mellert F, Fimmers R, Schrickel J, Nickenig G, Schwab JO. Independent predictors of mortality in patients with advanced heart failure treated by cardiac resynchronization therapy. Europace. 2012:1596-1601. [pmid: 22611058].
Leenders GE, De Boeck BW, Teske AJ, Meine M, Bogaard MD, Prinzen FW, Doevendans PA, Cramer MJ. Septal rebound stretch is a strong predictor of outcome after cardiac resynchronization therapy. J Card Fail. 2012:404-412. [pmid: 22555272].
Bank AJ, Rischall A, Gage RM, Burns KV, Kubo SH. Comparison of cardiac resynchronization therapy outcomes in patients with New York Heart Association functional class I/II versus III/IV heart failure. J Card Fail. 2012:373-378. [pmid: 22555266].
Celebi O, Knaus T, Blaschke F, Habedank D, Dohner W, Nitardy A, Stockburger M. Extraordinarily favorable left ventricular reverse remodeling through long-term cardiac resynchronization: super-response to cardiac resynchronization. Pacing Clin Electrophysiol. 2012:870-876. [pmid: 22553930].
Tomczak CR, Paterson I, Haykowsky MJ, Lawrance R, Martellotto A, Pantano A, Gulamhusein S, Haennel RG. Cardiac resynchronization therapy modulation of exercise left ventricular function and pulmonary O(2) uptake in heart failure. Am J Physiol Heart Circ Physiol. 2012:H2635-H2645. [pmid: 22523249].
Stefan L, Sedlacek K, Cerna D, Kryze L, Vancura V, Marek T, Kautzner J. Small left atrium and mild mitral regurgitation predict super-response to cardiac resynchronization therapy. Europace. 2012:1608-1614. [pmid: 22490374].
Malecka B, Zabek A, Maziarz A, Lelakowski J. Influence of heart failure etiology on the effect of upgrading from right ventricular apical to biventricular or bifocal pacing in patients with permanent atrial fibrillation and advanced heart failure. Pol Arch Med Wewn. 2012:89-97. [pmid: 22415222].
Sweeney MO, Sakaguchi S, Simons G, Machado C, Connett JE, Yang F. Response to the Center for Medicare &amp; Medicaid Services coverage with evidence development request for primary prevention implantable cardioverter-defibrillators: data from the OMNI study. Heart Rhythm. 2012:1058-1066. [pmid: 22387371].
Limongelli G, Roselli T, Pacileo G, Calabro P, Maddaloni V, Masarone D, Riegler L, Gravino R, Scarafile R, Salerno G, Miele T, D'Andrea A, Santangelo L, Romano M, Di Salvo G, Russo MG, Calabro R. Effect of cardiac resynchronization therapy on cardiotrophin-1 circulating levels in patients with heart failure. Intern Emerg Med. 2014:43-50. [pmid: 22179744].
Alpendurada F, Guha K, Sharma R, Ismail TF, Clifford A, Banya W, Mohiaddin RH, Pennell DJ, Cowie MR, McDonagh T, Prasad SK. Right ventricular dysfunction is a predictor of non-response and clinical outcome following cardiac resynchronization therapy. J Cardiovasc Magn Reson. 2011:68. [pmid: 22040270].
Edner M, Ring M, Henriksson P. Pre-implant right ventricular function might be an important predictor of the response to cardiac resynchronization therapy. Cardiovasc Ultrasound. 2011:28. [pmid: 22029550].
Theodorakis G, Katsikis A, Livanis E, Kostopoulou A, Adamopoulos S, Tsiapras D, Voudris V. Long term effects of cardiac resynchronization therapy in non-ambulatory NYHA IV heart failure patients. Pacing Clin Electrophysiol. 2011:1553-1560. [pmid: 21913946].
Celikyurt U, Agacdiken A, Geyik B, Kozdag G, Vural A, Ural D. Effect of cardiac resynchronization therapy on thyroid function. Clin Cardiol. 2011:703-705. [pmid: 21887693].
Lenarczyk R, Wozniak A, Kowalski O, Sokal A, Pruszkowska-Skrzep P, Sredniawa B, Szulik M, Zielinska T, Kukulski T, Stabryla J, Mazurek M, Bialkowski J, Kalarus Z. Effect of cardiac resynchronization on gradient reduction in patients with obstructive hypertrophic cardiomyopathy: preliminary study. Pacing Clin Electrophysiol. 2011:1544-1552. [pmid: 21834852].
Hotta VT, Martinelli Filho M, Mady C, Mathias W Jr, Vieira ML. Comparison between 2D and 3D echocardiography in the evaluation of reverse remodeling after CRT. Arq Bras Cardiol. 2011:111-121. [pmid: 21691680].
Shen X, Nair CK, Aronow WS, Hee T, Esterbrooks DJ. Effect of carvedilol versus metoprolol CR/XL on mortality in patients with heart failure treated with cardiac resynchronization therapy: a COX multivariate regression analysis. Am J Ther. 2013:247-253. [pmid: 21642836].
Aarones M, Gullestad L, Aakhus S, Ueland T, Skaardal R, Aass H, Wergeland R, Smith HJ, Aukrust P, Kongsgaard E. Prognostic value of cardiac troponin T in patients with moderate to severe heart failure scheduled for cardiac resynchronization therapy. Am Heart J. 2011:1031-1037. [pmid: 21641347].
Vural A, Agacdiken A, Celikyurt U, Culha M, Kahraman G, Kozdag G, Ural D. Effect of cardiac resynchronization therapy on libido and erectile dysfunction. Clin Cardiol. 2011:437-441. [pmid: 21638287].
Altman RK, McCarty D, Chen-Tournoux AA, Tournoux FB, Riedl L, Orencole M, Park MY, Picard MH, Singh JP. Usefulness of low-dose dobutamine echocardiography to predict response and outcome in patients undergoing cardiac resynchronization therapy. Am J Cardiol. 2011:252-27. [pmid: 21550579].
Mooyaart EA, Marsan NA, van Bommel RJ, Thijssen J, Borleffs CJ, Delgado V, van der Wall EE, Schalij MJ, Bax JJ. Comparison of long-term survival of men versus women with heart failure treated with cardiac resynchronization therapy. Am J Cardiol. 2011:63-68. [pmid: 21529733].
Prochnau D, Kuehnert H, Heinke M, Figulla HR, Surber R. Left ventricular lead position and nonspecific conduction delay are predictors of mortality in patients during cardiac resynchronization therapy. Can J Cardiol. 2011:363-368. [pmid: 21507601].
Tompkins C, McLean R, Cheng A, Brinker JA, Marine JE, Nazarian S, Spragg DD, Sinha S, Halperin H, Tomaselli GF, Berger RD, Calkins H, Henrikson CA. End-stage renal disease predicts complications in pacemaker and ICD implants. J Cardiovasc Electrophysiol. 2011:1099-1104. [pmid: 21489029].
Wilinski J, Czarnecka D, Wojciechowska W, Kloch-Badelek M, Jastrzebski M, Bacior B, Sondej T, Kusak P, Przybyla A, Kawecka-Jaszcz K. Clinical and classic echocardiographic features of patients with, and without, left ventricle reverse remodeling following the introduction of cardiac resynchronization therapy. Cardiol J. 2011:157-164. [pmid: 21432822].
Adelstein E, Schwartzman D, Gorcsan J 3rd, Saba S. Predicting hyperresponse among pacemaker-dependent nonischemic cardiomyopathy patients upgraded to cardiac resynchronization. J Cardiovasc Electrophysiol. 2011:905-911. [pmid: 21332868].
Kirubakaran S, Ladwiniec A, Arujuna A, Ginks M, McPhail M, Bostock J, Carr-White G, Rinaldi CA. Male gender and chronic obstructive pulmonary disease predict a poor clinical response in patients undergoing cardiac resynchronisation therapy. Int J Clin Pract. 2011:281-288. [pmid: 21314865].
Scheffer MG, van Dessel PF, van Gelder BM, Sutherland GR, van Hemel NM. Peak longitudinal strain delay is superior to TDI in the selection of patients for resynchronisation therapy. Neth Heart J. 2010:574-582.
Leyva F, Foley PW, Chalil S, Irwin N, Smith RE. Female gender is associated with a better outcome after cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2011:82-88. [pmid: 21214589].
Bertini M, Ziacchi M, Biffi M, Biagini E, Rocchi G, Martignani C, Ferlito M, Pasquale F, Cervi E, Branzi A, Rapezzi C, Boriani G. Effects of cardiac resynchronisation therapy on dilated cardiomyopathy with isolated ventricular non-compaction. Heart. 2011:295-300. [pmid: 21163889].
Clements IP, Christenson S, Hodge DO, Mullan BP, Redfield MM, Hayes DL. Symptom improvement after upgrade from right ventricular apical to biventricular pacing: Role of right and left ventricular volumes assessed with single-photon emission computed tomographic equilibrium radionuclide angiocardiography. J Nucl Cardiol. 2011:43-51. [pmid: 21128041].
Chaudhry FA, Shah A, Bangalore S, DeRose J, Steinberg JS. Inotropic contractile reserve and response to cardiac resynchronization therapy in patients with markedly remodeled left ventricle. J Am Soc Echocardiogr. 2011:91-97. [pmid: 21126856].
Schaer B, Theuns DA, Sticherling C, Szili-Torok T, Osswald S, Jordaens L. Effect of implantable cardioverter-defibrillator on left ventricular ejection fraction in patients with idiopathic dilated cardiomyopathy. Am J Cardiol. 2010:1640-1645. [pmid: 21094367].
Tereshchenko LG, Henrikson CA, Stempniewicz P, Han L, Berger RD. Antiarrhythmic effect of reverse electrical remodeling associated with cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2011:357-364. [pmid: 21091740].
Foley PW, Chalil S, Khadjooi K, Irwin N, Smith RE, Leyva F. Left ventricular reverse remodelling, long-term clinical outcome, and mode of death after cardiac resynchronization therapy. Eur J Heart Fail. 2011:43-51. [pmid: 21051462].
Gorcsan J 3rd, Oyenuga O, Habib PJ, Tanaka H, Adelstein EC, Hara H, McNamara DM, Saba S. Relationship of echocardiographic dyssynchrony to long-term survival after cardiac resynchronization therapy. Circulation. 2010:1910-1918. [pmid: 20975000].
Castellant P, Orhan E, Bertault-Valls V, Fatemi M, Etienne Y, Blanc JJ. Is &quot;hyper response&quot; to cardiac resynchronization therapy in patients with nonischemic cardiomyopathy a recovery, a remission, or a control?. Ann Noninvasive Electrocardiol. 2010:321-327. [pmid: 20946554].
Schaer BA, Osswald S, Di Valentino M, Soliman OI, Sticherling C, ten Cate FJ, Jordaens L, Theuns DA. Close connection between improvement in left ventricular function by cardiac resynchronization therapy and the incidence of arrhythmias in cardiac resynchronization therapy-defibrillator patients. Eur J Heart Fail. 2010:1325-1332. [pmid: 20923856].
van Bommel RJ, van Rijnsoever E, Borleffs CJ, Delgado V, Marsan NA, Bertini M, Schalij MJ, Bax JJ. Effect of cardiac resynchronization therapy in patients with New York Heart Association functional class IV heart failure. Am J Cardiol. 2010:1146-1151. [pmid: 20920655].
Aksoy H, Okutucu S, Aytemir K, Kaya EB, Tulumen E, Evranos B, Fatihoglu SG, Kabakci G, Tokgozoglu L, Ozkutlu H, Oto A. Improvement in right ventricular systolic function after cardiac resynchronization therapy correlates with left ventricular reverse remodeling. Pacing Clin Electrophysiol. 2011:200-207. [pmid: 20883514].
Bank AJ, Kaufman CL, Burns KV, Parah JS, Johnson L, Kelly AS, Shroff SG, Kaiser DR. Intramural dyssynchrony and response to cardiac resynchronization therapy in patients with and without previous right ventricular pacing. Eur J Heart Fail. 2010:1317-1324. [pmid: 20864481].
Berger T, Zwick RH, Stuehlinger M, Dichtl W, Poelzl G, Edlinger M, Pachinger O, Hintringer F. Impact of oxygen uptake efficiency slope as a marker of cardiorespiratory reserve on response to cardiac resynchronization therapy. Clin Res Cardiol. 2011:159-166. [pmid: 20862588].
Sedlacek K, Burianova L, Mlcochova H, Peichl P, Marek T, Kautzner J. Isolated left ventricular pacing results in worse long-term clinical outcome when compared with biventricular pacing: a single-centre randomized study. Europace. 2010:1762-1768. [pmid: 20729533].
Bertini M, Delgado V, Nucifora G, Marsan NA, Ng AC, Shanks M, Van Bommel RJ, Borleffs CJ, Ewe SH, Boriani G, Biffi M, Schalij MJ, Bax JJ. Effect of cardiac resynchronization therapy on subendo- and subepicardial left ventricular twist mechanics and relation to favorable outcome. Am J Cardiol. 2010:682-687. [pmid: 20723646].
van Bommel RJ, Borleffs CJ, Ypenburg C, Marsan NA, Delgado V, Bertini M, van der Wall EE, Schalij MJ, Bax JJ. Morbidity and mortality in heart failure patients treated with cardiac resynchronization therapy: influence of pre-implantation characteristics on long-term outcome. Eur Heart J. 2010:2783-2790. [pmid: 20693544].
Muto C, Gasparini M, Neja CP, Iacopino S, Davinelli M, Zanon F, Dicandia C, Distefano G, Donati R, Calvi V, Denaro A, Tuccillo B. Presence of left ventricular contractile reserve predicts midterm response to cardiac resynchronization therapy--results from the LOw dose DObutamine stress-echo test in Cardiac Resynchronization Therapy (LODO-CRT) trial. Heart Rhythm. 2010:1600-1605. [pmid: 20691283].
Miyazaki C, Redfield MM, Powell BD, Lin GM, Herges RM, Hodge DO, Olson LJ, Hayes DL, Espinosa RE, Rea RF, Bruce CJ, Nelson SM, Miller FA, Oh JK. Dyssynchrony indices to predict response to cardiac resynchronization therapy: a comprehensive prospective single-center study. Circ Heart Fail. 2010:565-573. [pmid: 20647479].
Bisch L, Da Costa A, Dauphinot V, Romeyer-Bouchard C, Khris L, M'baye A, Isaaz K. Predictive factors of difficult implantation procedure in cardiac resynchronization therapy. Europace. 2010:1141-1148. [pmid: 20573673].
Castel MA, Magnani S, Mont L, Roig E, Tamborero D, Mendez-Zurita F, Femenia JF, Tolosana JM, Perez-Villa F, Brugada J. Survival in New York Heart Association class IV heart failure patients treated with cardiac resynchronization therapy compared with patients on optimal pharmacological treatment. Europace. 2010:1136-1140. [pmid: 20543199].
Chen TB, Cheng KA, Gao P, Cheng ZW, Fan JB, Jiang XC, Fang Q. Primary prevention of sudden cardiac death by implantable cardioverter-defibrillator therapy in Chinese patients with heart failure: a single-center experience. Chin Med J (Engl). 2010:848-851. [pmid: 20497676].
Lipoldova J, Ozabalova E, Meluzin J, Novak M, Vitovec J. Usefulness of left ventricle dyssynchrony assessment before cardiac resynchronization implantation. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. 2010:39-46. [pmid: 20445710].
Jaussaud J, Blanc P, Derval N, Bordachar P, Courregelongue M, Roudaut R, Douard H. Ventilatory response and peak circulatory power: new functional markers of response after cardiac resynchronization therapy. Arch Cardiovasc Dis. 2010:184-191. [pmid: 20417450].
Reant P, Zaroui A, Donal E, Mignot A, Bordachar P, Deplagne A, Solnon A, Ritter P, Daubert JC, Clementy J, Leclercq C, Roudaut R, Habib G, Lafitte S. Identification and characterization of super-responders after cardiac resynchronization therapy. Am J Cardiol. 2010:1327-1335. [pmid: 20403487].
Soliman OI, Theuns DA, van Dalen BM, Vletter WB, Nemes A, Jordaens LJ, Balk AH, Ten Cate FJ, Geleijnse ML. Prediction of appropriate defibrillator therapy in heart failure patients treated with cardiac resynchronization therapy. Am J Cardiol. 2010:105-111. [pmid: 20102900].
Sweeney MO, van Bommel RJ, Schalij MJ, Borleffs CJ, Hellkamp AS, Bax JJ. Analysis of ventricular activation using surface electrocardiography to predict left ventricular reverse volumetric remodeling during cardiac resynchronization therapy. Circulation. 2010:626-634. [pmid: 20100970].
van Geldorp IE, Vernooy K, Delhaas T, Prins MH, Crijns HJ, Prinzen FW, Dijkman B. Beneficial effects of biventricular pacing in chronically right ventricular paced patients with mild cardiomyopathy. Europace. 2010:223-229. [pmid: 19966323].
Cabrera-Bueno F, Molina-Mora MJ, Alzueta J, Pena-Hernandez J, Jimenez-Navarro M, Fernandez-Pastor J, Barrera A, de Teresa E. Persistence of secondary mitral regurgitation and response to cardiac resynchronization therapy. Eur J Echocardiogr. 2010:131-137. [pmid: 19939817].
Kronborg MB, Nielsen JC, Mortensen PT. Electrocardiographic patterns and long-term clinical outcome in cardiac resynchronization therapy. Europace. 2010:216-222. [pmid: 19915182].
Cabrera-Bueno F, Fernandez-Pastor J, Molina-Mora MJ, Alzueta J, Pena-Hernandez JL, Barrera A, de Teresa-Galvan E. Combined resynchronization therapy and automatic defibrillator in advanced non-ischaemic heart failure: the importance of QRS width. Europace. 2010:92-95. [pmid: 19897502].
Adlbrecht C, Hulsmann M, Gwechenberger M, Strunk G, Khazen C, Wiesbauer F, Elhenicky M, Neuhold S, Binder T, Maurer G, Lang IM, Pacher R. Outcome after device implantation in chronic heart failure is dependent on concomitant medical treatment. Eur J Clin Invest. 2009:1073-1081. [pmid: 19843157].
El-Saed A, Voigt A, Shalaby A. Usefulness of brain natriuretic peptide level at implant in predicting mortality in patients with advanced but stable heart failure receiving cardiac resynchronization therapy. Clin Cardiol. 2009:E33-E38. [pmid: 19816874].
Pfau G, Schilling T, Kozian A, Lux A, Gotte A, Huth C, Hachenberg T. Outcome after implantation of cardiac resynchronization/defibrillation systems in patients with congestive heart failure and left bundle-branch block. J Cardiothorac Vasc Anesth. 2010:30-36. [pmid: 19800818].
Delnoy PP, Ottervanger JP, Luttikhuis HO, Elvan A, Misier AR, Beukema WP, van Hemel NM. Long-term clinical response of cardiac resynchronization after chronic right ventricular pacing. Am J Cardiol. 2009:116-121. [pmid: 19576330].
Vatankulu MA, Goktekin O, Kaya MG, Ayhan S, Kucukdurmaz Z, Sutton R, Henein M. Effect of long-term resynchronization therapy on left ventricular remodeling in pacemaker patients upgraded to biventricular devices. Am J Cardiol. 2009:1280-1284. [pmid: 19406272].
Foley PW, Chalil S, Khadjooi K, Jordan P, Smith RE, Frenneaux MP, Leyva F. Effects of cardiac resynchronization therapy in patients unselected for mechanical dyssynchrony. Int J Cardiol. 2010:51-56. [pmid: 19246108].
Antonio N, Teixeira R, Coelho L, Lourenco C, Monteiro P, Ventura M, Cristovao J, Elvas L, Goncalves L, Providencia LA. Identification of 'super-responders' to cardiac resynchronization therapy: the importance of symptom duration and left ventricular geometry. Europace. 2009:343-349. [pmid: 19240109].
Ypenburg C, van Bommel RJ, Borleffs CJ, Bleeker GB, Boersma E, Schalij MJ, Bax JJ. Long-term prognosis after cardiac resynchronization therapy is related to the extent of left ventricular reverse remodeling at midterm follow-up. J Am Coll Cardiol. 2009:483-490. [pmid: 19195605].
D'Andrea A, Caso P, Scarafile R, Riegler L, Salerno G, Castaldo F, Gravino R, Cocchia R, Del Viscovo L, Limongelli G, Di Salvo G, Ascione L, Iengo R, Cuomo S, Santangelo L, Calabro R. Effects of global longitudinal strain and total scar burden on response to cardiac resynchronization therapy in patients with ischaemic dilated cardiomyopathy. Eur J Heart Fail. 2009:58-67. [pmid: 19147458].
Kelarijani RB, Saleh DK, Chalian M, Kabir A, Ahmadzad Asl M, Dadjoo Y. Gender- and age-related outcomes of cardiac resynchronization therapy: a pilot observational study. Gend Med. 2008:415-422. [pmid: 19108814].
Garcia-Seara J, Martinez-Sande JL, Cid B, Gude F, Bastos M, Dominguez M, Varela A, Gonzalez-Juanatey JR. Influence of the preimplantation QRS axis on responses to cardiac resynchronization therapy. Rev Esp Cardiol. 2008:1245-1252. [pmid: 19080962].
Yiu KH, Lee KL, Lau CP, Siu CW, Miu KM, Lam B, Lam J, Ip MS, Tse HF. Alleviation of pulmonary hypertension by cardiac resynchronization therapy is associated with improvement in central sleep apnea. Pacing Clin Electrophysiol. 2008:1522-1527. [pmid: 19067803].
Fung JW, Lam YY, Zhang Q, Yip GW, Chan WW, Chan GC, Chan JY, Yu CM. Effect of left ventricular lead concordance to the delayed contraction segment on echocardiographic and clinical outcomes after cardiac resynchronization therapy. J Cardiovasc Electrophysiol. 2009:530-535. [pmid: 19054250].
Knebel F, Schattke S, Bondke H, Richter C, Melzer C, Dreger H, Grohmann A, Baumann G, Borges AC. Implementation of seven echocardiographic parameters of myocardial asynchrony to improve the long-term response rate of cardiac resynchronization therapy (CRT). Cardiovasc Ultrasound. 2008:58. [pmid: 19032733].
Mangiavacchi M, Gasparini M, Genovese S, Pini D, Klersy C, Bragato R, Andreuzzi B, Municino A, Regoli F, Galimberti P, Ceriotti C, Gronda E. Insulin-treated type 2 diabetes is associated with a decreased survival in heart failure patients after cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2008:1425-1432. [pmid: 18950300].
Donal E, Thibault H, Bergerot C, Leroux PY, Cannesson M, Thivolet S, Barthelet M, Rivard L, Chevalier P, Ovize M, Daubert JC, Leclerq C, Mabo P, Derumeaux G. Right ventricular pump function after cardiac resynchronization therapy: a strain imaging study. Arch Cardiovasc Dis. 2008:475-484. [pmid: 18848690].
Kimura S, Ito M, Chinushi M, Tanaka K, Tanabe Y, Hosaka Y, Komura S, Okada S, Iijima K, Furushima H, Fuse K, Sato M, Aizawa Y. Preservation of renal function in response to cardiac resynchronization therapy. Circ J. 2008:1794-1799. [pmid: 18838826].
Landolina M, Gasparini M, Lunati M, Santini M, Rordorf R, Vincenti A, Diotallevi P, Montenero AS, Bonanno C, De Santo T, Valsecchi S, Padeletti L. Heart rate variability monitored by the implanted device predicts response to CRT and long-term clinical outcome in patients with advanced heart failure. Eur J Heart Fail. 2008:1073-1079. [pmid: 18838333].
Nagele H, Dodeck J, Behrens S, Azizi M, Hashagen S, Eisermann C, Castel MA. Hemodynamics and prognosis after primary cardiac resynchronization system implantation compared to &quot;upgrade&quot; procedures. Pacing Clin Electrophysiol. 2008:1265-1271. [pmid: 18811806].
Hina K, Kawamura H, Murakami T, Yamamoto K, Yamaji H, Murakami M, Hirohata S, Ogawa H, Sakane K, Kusachi S. Association of corrected QT dispersion with symptoms improvement in patients receiving cardiac resynchronization therapy. Heart Vessels. 2008:325-333. [pmid: 18810581].
Riedlbauchova L, Brunken R, Jaber WA, Popova L, Patel D, Lanska V, Civello K, Cummings J, Burkhardt JD, Saliba W, Martin D, Schweikert R, Wilkoff BL, Grimm R, Natale A. The impact of myocardial viability on the clinical outcome of cardiac resynchronization therapy. J Cardiovasc Electrophysiol. 2009:50-57. [pmid: 18803571].
Marsan NA, Bleeker GB, Ypenburg C, Van Bommel RJ, Ghio S, Van de Veire NR, Delgado V, Holman ER, van der Wall EE, Schalij MJ, Bax JJ. Real-time three-dimensional echocardiography as a novel approach to assess left ventricular and left atrium reverse remodeling and to predict response to cardiac resynchronization therapy. Heart Rhythm. 2008:1257-1264. [pmid: 18774099].
Akar JG, Al-Chekakie MO, Fugate T, Moran L, Froloshki B, Varma N, Santucci P, Wilber DJ, Matsumura ME. Endothelial dysfunction in heart failure identifies responders to cardiac resynchronization therapy. Heart Rhythm. 2008:1229-1235. [pmid: 18774094].
Umar S, Bax JJ, Klok M, van Bommel RJ, Hessel MH, den Adel B, Bleeker GB, Henneman MM, Atsma DE, van der Wall EE, Schalij MJ, van der Laarse A. Myocardial collagen metabolism in failing hearts before and during cardiac resynchronization therapy. Eur J Heart Fail. 2008:878-883. [pmid: 18768351].
Menardi E, Vado A, Rossetti G, Racca E, Conte E, Deorsola A, Bobbio M, Feola M. Cardiac resynchronization therapy modifies the neurohormonal profile, hemodynamic and functional capacity in heart failure patients. Arch Med Res. 2008:702-708. [pmid: 18760200].
Fazelifar AF, Bonakdar HR, Alizadeh K, Azarnik H, Haghjoo M, Abkenar HB, Samiei N, Sadr-Ameli MA. Relationship between QRS complex notch and ventricular dyssynchrony in patients with heart failure and prolonged QRS duration. Cardiol J. 2008:351-356. [pmid: 18698544].
Buck S, Maass AH, Nieuwland W, Anthonio RL, Van Veldhuisen DJ, Van Gelder IC. Impact of interventricular lead distance and the decrease in septal-to-lateral delay on response to cardiac resynchronization therapy. Europace. 2008:1313-1319. [pmid: 18694907].
Tolosana JM, Hernandez Madrid A, Brugada J, Sitges M, Garcia Bolao I, Fernandez Lozano I, Martinez Ferrer J, Quesada A, Macias A, Marin W, Escudier JM, Gomez AA, Gimenez Alcala M, Tamborero D, Berruezo A, Mont L. Comparison of benefits and mortality in cardiac resynchronization therapy in patients with atrial fibrillation versus patients in sinus rhythm (Results of the Spanish Atrial Fibrillation and Resynchronization. Am J Cardiol. 2008:444-449. [pmid: 18678303].
Cleland J, Freemantle N, Ghio S, Fruhwald F, Shankar A, Marijanowski M, Verboven Y, Tavazzi L. Predicting the long-term effects of cardiac resynchronization therapy on mortality from baseline variables and the early response a report from the CARE-HF (Cardiac Resynchronization in Heart Failure) Trial. J Am Coll Cardiol. 2008:438-445. [pmid: 18672164].
Zhang Q, Fung JW, Chan JY, Yip G, Lam YY, Liang YJ, Yu CM. Difference in long-term clinical outcome after cardiac resynchronisation therapy between ischaemic and non-ischaemic aetiologies of heart failure. Heart. 2009:113-118. [pmid: 18653570].
Kronborg MB, Mortensen PT, Kirkfeldt RE, Nielsen JC. Very long term follow-up of cardiac resynchronization therapy: clinical outcome and predictors of mortality. Eur J Heart Fail. 2008:796-801. [pmid: 18619900].
Zanon F, Aggio S, Baracca E, Pastore G, Corbucci G, Boaretto G, Braggion G, Piergentili C, Rigatelli G, Roncon L. Ventricular-arterial coupling in patients with heart failure treated with cardiac resynchronization therapy: may we predict the long-term clinical response?. Eur J Echocardiogr. 2009:106-111. [pmid: 18579495].
Soliman OI, van Dalen BM, Theuns DA, ten Cate FJ, Nemes A, Jordaens LJ, Geleijnse ML. The ischemic etiology of heart failure in diabetics limits reverse left ventricular remodeling after cardiac resynchronization therapy. J Diabetes Complications. 2009:365-370. [pmid: 18572420].
Di Biase L, Auricchio A, Sorgente A, Civello K, Klersy C, Faletra F, Riedlbauchova L, Patel D, Arruda M, Schweikert RA, Martin DO, Saliba WI, Moccetti T, Wilkoff BL, Natale A. The magnitude of reverse remodelling irrespective of aetiology predicts outcome of heart failure patients treated with cardiac resynchronization therapy. Eur Heart J. 2008:2497-2505. [pmid: 18515806].
Kirn B, Jansen A, Bracke F, van Gelder B, Arts T, Prinzen FW. Mechanical discoordination rather than dyssynchrony predicts reverse remodeling upon cardiac resynchronization. Am J Physiol Heart Circ Physiol. 2008:H640-H646. [pmid: 18515652].
Chwyczko T, Sterlinski M, Maciag A, Firek B, Labecka A, Jankowska A, Kosmicki M, Kowalik I, Malczewska B, Szwed H. Impact of cardiac resynchronisation therapy on adaptation of circulatory and respiratory systems to exercise assessed by cardiopulmonary exercise test in patients with chronic heart failure. Kardiol Pol. 2008:406-412. discussion 413-4. [pmid: 18473269].
Faran A, Dabrowska-Kugacka A, Lewicka-Nowak E, Tybura S, Zieba B, Danilowicz-Szymanowicz L, Krzyminska-Stasiuk E, Kempa M, Kogut K, Raczak G. Echocardiographic evaluation of patients with severe heart failure and impairment of intraventricular conduction following cardiac resynchronisation therapy. Kardiol Pol. 2008:396-403. discussion 404-5. [pmid: 18473268].
Goscinska-Bis K, Bis J, Krejca M, Ulczok R, Szmagala P, Bochenek A, Kargul W. Totally epicardial cardiac resynchronization therapy system implantation in patients with heart failure undergoing CABG. Eur J Heart Fail. 2008:498-506. [pmid: 18413295].
Rogers DP, Marazia S, Chow AW, Lambiase PD, Lowe MD, Frenneaux M, McKenna WJ, Elliott PM. Effect of biventricular pacing on symptoms and cardiac remodelling in patients with end-stage hypertrophic cardiomyopathy. Eur J Heart Fail. 2008:507-513. [pmid: 18406204].
Silva RT, Martinelli Filho M, Lima CE, Martins DG, Nishioka SA, Pedrosa AA, Crevelari ES, Costa R, Sosa EA, Ramires JA. Functional behavior of patients with conventional pacemakers undergoing cardiac resynchronization. Arq Bras Cardiol. 2008:138-143. [pmid: 18392387].
Milliez P, Thomas O, Haggui A, Schurando P, Squara P, Cohen-Solal A, Mebazaa A, Leenhardt A. Cardiac resynchronisation as a rescue therapy in patients with catecholamine-dependent overt heart failure: results from a short and mid-term study. Eur J Heart Fail. 2008:291-297. [pmid: 18313982].
Burri H, Sunthorn H, Somsen A, Fleury E, Stettler C, Shah D, Righetti A. Improvement in cardiac sympathetic nerve activity in responders to resynchronization therapy. Europace. 2008:374-378. [pmid: 18308757].
Faran A, Lewicka-Nowak E, Dabrowska-Kugacka A, Kempa M, Tybura S, Szwoch M, Krolak T, Raczak G. Cardiac resynchronisation therapy in patients with end-stage heart failure--long-term follow-up. Kardiol Pol. 2008:19-26. discussion 27. [pmid: 18266184].
Vanderheyden M, Mullens W, Delrue L, Goethals M, de Bruyne B, Wijns W, Geelen P, Verstreken S, Wellens F, Bartunek J. Myocardial gene expression in heart failure patients treated with cardiac resynchronization therapy responders versus nonresponders. J Am Coll Cardiol. 2008:129-136. [pmid: 18191736].
Wojcicka M, Sterlinski M, Chwyczko T, Smolis-Bak E, Szwed H, Kowalik I. Quality of life in patients undergoing cardiac resynchronisation therapy. Kardiol Pol. 2007:1425-1430. discussion 1431-2. [pmid: 18181054].
Shalaby A, Voigt A, El-Saed A, Saba S. Usefulness of pulmonary artery pressure by echocardiography to predict outcome in patients receiving cardiac resynchronization therapy heart failure. Am J Cardiol. 2008:238-241. [pmid: 18178413].
Stollberger C, Blazek G, Bucher E, Finsterer J. Cardiac resynchronization therapy in left ventricular hypertrabeculation/non-compaction and myopathy. Europace. 2008:59-62. [pmid: 18029382].
Varma N, Jia P, Rudy Y. Electrocardiographic imaging of patients with heart failure with left bundle branch block and response to cardiac resynchronization therapy. J Electrocardiol. 2007:S174-S178. [pmid: 17993318].
Buch E, Lellouche N, De Diego C, Vaseghi M, Cesario DA, Fujimura O, Wiener I, Child JS, Boyle NG, Shivkumar K. Left ventricular apical wall motion abnormality is associated with lack of response to cardiac resynchronization therapy in patients with ischemic cardiomyopathy. Heart Rhythm. 2007:1300-1305. [pmid: 17905335].
Raab S, Oertel F, Weimann T, Danov V, Beyer M. Brain natriuretic peptide--a reliable parameter for the effectiveness of cardiac resynchronization therapy after coronary artery bypass grafting. Interact Cardiovasc Thorac Surg. 2006:439-443. [pmid: 17670611].
Stanchina ML, Ellison K, Malhotra A, Anderson M, Kirk M, Benser ME, Tosi C, Carlisle C, Millman RP, Buxton A. The impact of cardiac resynchronization therapy on obstructive sleep apnea in heart failure patients: a pilot study. Chest. 2007:433-439. [pmid: 17573498].
Cabrera-Bueno F, Garcia-Pinilla JM, Pena-Hernandez J, Jimenez-Navarro M, Gomez-Doblas JJ, Barrera-Cordero A, Alzueta-Rodriguez J, de Teresa-Galvan E. Repercussion of functional mitral regurgitation on reverse remodelling in cardiac resynchronization therapy. Europace. 2007:757-761. [pmid: 17573358].
Yuan XP, White JA, Yee R, Drangova M. Tissue Doppler imaging of mitral annular motion is an effective surrogate of left ventricular dyssynchrony and predicts response to cardiac resynchronization therapy. J Am Soc Echocardiogr. 2007:1186-1193. [pmid: 17570638].
Shimano M, Tsuji Y, Yoshida Y, Inden Y, Tsuboi N, Itoh T, Suzuki H, Muramatsu T, Okada T, Harata S, Yamada T, Hirayama H, Nattel S, Murohara T. Acute and chronic effects of cardiac resynchronization in patients developing heart failure with long-term pacemaker therapy for acquired complete atrioventricular block. Europace. 2007:869-874. [pmid: 17557768].
Richardson M, Freemantle N, Calvert MJ, Cleland JG, Tavazzi L. Predictors and treatment response with cardiac resynchronization therapy in patients with heart failure characterized by dyssynchrony: a pre-defined analysis from the CARE-HF trial. Eur Heart J. 2007:1827-1834. [pmid: 17540848].
Madaric J, Vanderheyden M, Van Laethem C, Verhamme K, Feys A, Goethals M, Verstreken S, Geelen P, Penicka M, De Bruyne B, Bartunek J. Early and late effects of cardiac resynchronization therapy on exercise-induced mitral regurgitation: relationship with left ventricular dyssynchrony, remodelling and cardiopulmonary performance. Eur Heart J. 2007:2134-2141. [pmid: 17504802].
Lane RE, Mayet J, Peters NS, Davies DW, Chow AW. Comparison of temporary bifocal right ventricular pacing and biventricular pacing for heart failure: evaluation by tissue Doppler imaging. Heart. 2008:53-58. [pmid: 17483133].
Oldenburg O, Faber L, Vogt J, Dorszewski A, Szabados F, Horstkotte D, Lamp B. Influence of cardiac resynchronisation therapy on different types of sleep disordered breathing. Eur J Heart Fail. 2007:820-826. [pmid: 17467333].
Stern J, Heist EK, Murray L, Alabiad C, Chung J, Picard MH, Semigran MJ, Ruskin JN, Singh JP. Elevated estimated pulmonary artery systolic pressure is associated with an adverse clinical outcome in patients receiving cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2007:603-607. [pmid: 17461868].
Penicka M, Vanderheyden M, Geelen P, Mortier L, Goethals M, Verstreken S, Karasek J, De Bruyne B, Bartunek J. Tissue Doppler predicts long-term clinical outcome after cardiac resynchronization therapy. Int J Cardiol. 2008:40-46. [pmid: 17383748].
Saxon LA, Bristow MR, Boehmer J, Krueger S, Kass DA, De Marco T, Carson P, DiCarlo L, Feldman AM, Galle E, Ecklund F. Predictors of sudden cardiac death and appropriate shock in the Comparison of Medical Therapy, Pacing, and Defibrillation in Heart Failure (COMPANION) Trial. Circulation. 2006:2766-2772. [pmid: 17159063].
Mansour M, Rasche V, Picard MH, Ruskin JN. Integration of three-dimensional coronary venous angiography with three-dimensional echocardiography for biventricular device implantation. Heart Rhythm. 2006:1391-1392. [pmid: 17074653].
Singh JP, Fan D, Heist EK, Alabiad CR, Taub C, Reddy V, Mansour M, Picard MH, Ruskin JN, Mela T. Left ventricular lead electrical delay predicts response to cardiac resynchronization therapy. Heart Rhythm. 2006:1285-1292. [pmid: 17074633].
Bai R, Yang XY, Song Y, Lin L, Lu JG, Ching CK, Pu J, Kam R, Hsu LF, Zhang CT, Teo WS, Wang L. Impact of left ventricular epicardial and biventricular pacing on ventricular repolarization in normal-heart individuals and patients with congestive heart failure. Europace. 2006:1002-1010. [pmid: 17043073].
Boriani G, Gasparini M, Lunati M, Santini M, Landolina M, Vincenti A, Curnis A, Bocchiardo M, Padeletti L, Biffi M, Allaria L, Denaro A. Characteristics of ventricular tachyarrhythmias occurring in ischemic versus nonischemic patients implanted with a biventricular cardioverter-defibrillator for primary or secondary prevention of sudden death. Am Heart J. 2006:527.e1-527.e11. [pmid: 16923425].
Bleeker GB, Schalij MJ, Holman ER, Steendijk P, van der Wall EE, Bax JJ. Cardiac resynchronization therapy in patients with systolic left ventricular dysfunction and symptoms of mild heart failure secondary to ischemic or nonischemic cardiomyopathy. Am J Cardiol. 2006:230-235. [pmid: 16828599].
Cowburn PJ, Patel H, Pipes RR, Parker JD. Contrast nephropathy post cardiac resynchronization therapy: an under-recognized complication with important morbidity. Eur J Heart Fail. 2005:899-903. [pmid: 15919239].
Kies P, Bax JJ, Molhoek SG, Bleeker GB, Zeppenfeld K, Bootsma M, van Erven L, Steendijk P, van der Wall EE, Schalij MJ. Effect of cardiac resynchronization therapy on inducibility of ventricular tachyarrhythmias in cardiac arrest survivors with either ischemic or idiopathic dilated cardiomyopathy. Am J Cardiol. 2005:1111-1114. [pmid: 15842986].
Braunschweig F, Mortensen PT, Gras D, Reiser W, Lawo T, Mansour H, Sogaard P, Stegemann B, Bruns HJ, Linde C. Monitoring of physical activity and heart rate variability in patients with chronic heart failure using cardiac resynchronization devices. Am J Cardiol. 2005:1104-1107. [pmid: 15842984].
Waggoner AD, Faddis MN, Gleva MJ, De Las Fuentes L, Osborn J, Heuerman S, Davila-Roman VG. Cardiac resynchronization therapy acutely improves diastolic function. J Am Soc Echocardiogr. 2005:216-220. [pmid: 15746709].
Lecoq G, Leclercq C, Leray E, Crocq C, Alonso C, de Place C, Mabo P, Daubert C. Clinical and electrocardiographic predictors of a positive response to cardiac resynchronization therapy in advanced heart failure. Eur Heart J. 2005:1094-1100. [pmid: 15728648].
Cowburn PJ, Patel H, Jolliffe RE, Wald RW, Parker JD. Cardiac resynchronization therapy: an option for inotrope-supported patients with end-stage heart failure?. Eur J Heart Fail. 2005:215-217. [pmid: 15701469].
Cleland JG, Daubert JC, Erdmann E, Freemantle N, Gras D, Kappenberger L, Klein W, Tavazzi L. Baseline characteristics of patients recruited into the CARE-HF study. Eur J Heart Fail. 2005:205-214. [pmid: 15701468].
Mair H, Sachweh J, Meuris B, Nollert G, Schmoeckel M, Schuetz A, Reichart B, Daebritz S. Surgical epicardial left ventricular lead versus coronary sinus lead placement in biventricular pacing. Eur J Cardiothorac Surg. 2005:235-242. [pmid: 15691676].
De Cock CC, Van Campen LM, Jessurun ER, Allaart CA, Vos DS, Visser CA. Long-term follow-up of patients with refractory heart failure and myocardial ischemia treated with cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2005:S8-S10. [pmid: 15683533].
Funck RC, Koelsch S, Waldhans S, Prinz H, Grimm W, Moosdorf R, Maisch B. Marked improvement in left ventricular function and significant reverse left ventricular remodeling within 3 months of cardiac resynchronization therapy in patients with dilated cardiomyopathy. Pacing Clin Electrophysiol. 2005:S5-S7. [pmid: 15683524].
Boriani G, Fallani F, Martignani C, Biffi M, Saporito D, Greco C, Ziacchi M, Levorato M, Pontone G, Valzania C, Diemberger I, Franchi R, Branzi A. Cardiac resynchronization therapy: effects on left and right ventricular ejection fraction during exercise. Pacing Clin Electrophysiol. 2005:S11-S14. [pmid: 15683474].
Capasso F, Giunta A, Stabile G, Turco P, La Rocca V, Grimaldi G, De Simone A. Left ventricular functional recovery during cardiac resynchronization therapy: predictive role of asynchrony measured by strain rate analysis. Pacing Clin Electrophysiol. 2005:S1-S4. [pmid: 15683471].
Inoue N, Ishikawa T, Sumita S, Nakagawa T, Kobayashi T, Matsushita K, Matsumoto K, Ohkusu Y, Taima M, Kosuge M, Uchino K, Kimura K, Umemura S. Long-term follow-up of atrioventricular delay optimization in patients with biventricular pacing. Circ J. 2005:201-204. [pmid: 15671613].
Tada H, Toide H, Naito S, Kurosaki K, Ito S, Miyaji K, Yamada M, Okaniwa H, Kobayashi Y, Maruyama H, Higuchi R, Nogami A, Oshima S, Taniguchi K. Tissue Doppler imaging and strain Doppler imaging as modalities for predicting clinical improvement in patients receiving biventricular pacing. Circ J. 2005:194-200. [pmid: 15671612].
Zanon F, Aggio S, Baracca E, Bilato C, Corbucci G, Rigatelli G, Zonzin P. Reduced mitral regurgitation in heart failure patients submitted to cardiac resynchronization therapy: a short-term prospective study. Ital Heart J. 2004:826-830. [pmid: 15633437].
Barbieri A, Bursi F, Bonatti S, Coppi F, Zanasi V, Reggianini L, Casali E, Malavasi VL, Modena MG. Evidence of reverse remodeling after long-term biventricular stimulation for resynchronization in patients with wide QRS selected on the basis of echocardiographic electromechanical delays. Ital Heart J. 2004:818-825. [pmid: 15633436].
Pitzalis MV, Iacoviello M, Romito R, Guida P, De Tommasi E, Luzzi G, Anaclerio M, Forleo C, Rizzon P. Ventricular asynchrony predicts a better outcome in patients with chronic heart failure receiving cardiac resynchronization therapy. J Am Coll Cardiol. 2005:65-69. [pmid: 15629375].
Yu CM, Lin H, Fung WH, Zhang Q, Kong SL, Sanderson JE. Comparison of acute changes in left ventricular volume, systolic and diastolic functions, and intraventricular synchronicity after biventricular and right ventricular pacing for heart failure. Am Heart J. 2003:E18. [pmid: 12766742].
Stellbrink C, Breithardt OA, Franke A, Sack S, Bakker P, Auricchio A, Pochet T, Salo R, Kramer A, Spinelli J. Impact of cardiac resynchronization therapy using hemodynamically optimized pacing on left ventricular remodeling in patients with congestive heart failure and ventricular conduction disturbances. J Am Coll Cardiol. 2001:1957-1965. [pmid: 11738300].
Garrigue S, Jais P, Espil G, Labeque JN, Hocini M, Shah DC, Haissaguerre M, Clementy J. Comparison of chronic biventricular pacing between epicardial and endocardial left ventricular stimulation using Doppler tissue imaging in patients with heart failure. Am J Cardiol. 2001:858-862. [pmid: 11676947].
Sogaard P, Kim WY, Jensen HK, Mortensen P, Pedersen AK, Kristensen BO, Egeblad H. Impact of acute biventricular pacing on left ventricular performance and volumes in patients with severe heart failure. A tissue doppler and three-dimensional echocardiographic study. Cardiology. 2001:173-182. [pmid: 11585992].
Zagrodzky JD, Ramaswamy K, Page RL, Joglar JA, Sheehan CJ, Smith ML, Hamdan MH. Biventricular pacing decreases the inducibility of ventricular tachycardia in patients with ischemic cardiomyopathy. Am J Cardiol. 2001:1208-1210. A7. [pmid: 11356402].
Kim WY, Sogaard P, Mortensen PT, Jensen HK, Pedersen AK, Kristensen BO, Egeblad H. Three dimensional echocardiography documents haemodynamic improvement by biventricular pacing in patients with severe heart failure. Heart. 2001:514-520. [pmid: 11303000].
Lau CP, Yu CM, Chau E, Fan K, Tse HF, Lee K, Tang MO, Wan SH, Law TC, Lee PY, Lam YM, Hill MR. Reversal of left ventricular remodeling by synchronous biventricular pacing in heart failure. Pacing Clin Electrophysiol. 2000:1722-1725. [pmid: 11139909].
Gaita F, Bocchiardo M, Porciani MC, Vivalda L, Colella A, Di Donna P, Caponi D, Bruzzone M, Padeletti L. Should stimulation therapy for congestive heart failure be combined with defibrillation backup?. Am J Cardiol. 2000:165K-158K.
Hamdan MH, Zagrodzky JD, Joglar JA, Sheehan CJ, Ramaswamy K, Erdner JF, Page RL, Smith ML. Biventricular pacing decreases sympathetic activity compared with right ventricular pacing in patients with depressed ejection fraction. Circulation. 2000:1027-1032. [pmid: 10961968].
Bakker PF, Meijburg HW, de Vries JW, Mower MM, Thomas AC, Hull ML, Robles De Medina EO, Bredee JJ. Biventricular pacing in end-stage heart failure improves functional capacity and left ventricular function. J Interv Card Electrophysiol. 2000:395-404. [pmid: 10936005].
Farwell D, Patel NR, Hall A, Ralph S, Sulke AN. How many people with heart failure are appropriate for biventricular resynchronization?. Eur Heart J. 2000:1246-1250. [pmid: 10924314].
Kerwin WF, Botvinick EH, O'Connell JW, Merrick SH, DeMarco T, Chatterjee K, Scheibly K, Saxon LA. Ventricular contraction abnormalities in dilated cardiomyopathy: effect of biventricular pacing to correct interventricular dyssynchrony. J Am Coll Cardiol. 2000:1221-1227. [pmid: 10758964].
Alonso C, Leclercq C, Victor F, Mansour H, de Place C, Pavin D, Carre F, Mabo P, Daubert JC. Electrocardiographic predictive factors of long-term clinical improvement with multisite biventricular pacing in advanced heart failure. Am J Cardiol. 99:1417-1421.
Stanton T, Haluska BA, Leano R, Marwick TH. Hemodynamic benefit of rest and exercise optimization of cardiac resynchronization therapy. Echocardiography. 2014.
Stankovic I, Aarones M, Smith H-J, Voros G, Kongsgaard E, Neskovic AN, Willems R, Aakhus S, Voigt J-U. Dynamic relationship of left-ventricular dyssynchrony and contractile reserve in patients undergoing cardiac resynchronization therapy. Eur. Heart. J. 2014:48-55a. [pmid: 23918757].
Rinaldi CA, Kranig W, Leclercq C, Kacet S, Betts T, Bordachar P, Gutleben K-J, Shetty A, Keel A, Ryu K, Farazi TG, Simon M, Naqvi TZ. Acute effects of multisite left ventricular pacing on mechanical dyssynchrony in patients receiving cardiac resynchronization therapy. J. Card. Fail. 2013:731-738. [pmid: 24263116].
Zaeem F, Giedriemiene D, Coleman C, Crespo E, Radojevic J, Zweibel S, Kluger J, Clyne CA. CRT-D therapy in patients with decompensated NYHA class-four CHF. Cardiol.Res. Pract. 2012.
Fumagalli S, Valsecchi S, Boriani G, Gasparini M, Landolina M, Lunati M, Padeletti M, Tronconi F, Marchionni N, Padeletti L. Comparison of the usefulness of cardiac resynchronization therapy in three age-groups (&lt;65, 65–74 and (greater-than or equal to)75 years) (from the InSync/InSync ICD Italian Registry). Am. J. Cardiol. 2011:1510-1516. [pmid: 21420060].
Lousinha A, Oliveira MM, Feliciano J, Galrinho A, Branco LM, Cunha PS, Hamad H, Ramos R, Abreu J, Leal A, Santos S, Soares R, Da Silva MN, Ferreira RC. Benefits of cardiac resynchronization therapy in &quot;Very dilated cardiomyopathy&quot;: Beneficios da terapeutica de ressincronizacao cardiaca na &lt;&lt;miocardiopatia muito dilatada&gt;&gt;. Rev. Port. Cardiol. 2011:283-294. [pmid: 21638987].
Bulur S, Vural A, YazIcI M, Ertas G, Ozhan H, Ural D. Incidence and predictors of subclavian vein obstruction following biventricular device implantation. J. Intervent. Card. Electrophysiol. 2010:199-202.
Cappelli F, Porciani MC, Ricceri I, Perrotta L, Ricciardi G, Pieragnoli P, Paladini G, Michelucci A, Padeletti L. Tricuspid annular plane systolic excursion evaluation improves selection of cardiac resynchronization therapy patients. Clin. Cardiol. 2010:578-582. [pmid: 20842743].
Ghanbari H, Feldman D, Schmidt M, Ottino J, MacHado C, Akoum N, Wall TS, Daccarett M. Cardiac resynchronization therapy device implantation in patients with therapeutic international normalized ratios. PACE Pacing Clin. Electrophysiol. 2010:400-406. [pmid: 20180915].
Cattadori G, Giraldi F, Berti M, Carbucicchio C, Pepi M, Della Bella P, Contini M, Apostolo A, Berna G, Andreini D, Sciomer S, Agostoni P. Assessment of cardiac resynchronization therapy response. Int. J. Cardiol. 2009:240-242. [pmid: 18672300].
Landolina M, Lunati M, Gasparini M, Santini M, Padeletti L, Achilli A, Bianchi S, Laurenzi F, Curnis A, Vincenti A, Valsecchi S, Denaro A. Comparison of the Effects of Cardiac Resynchronization Therapy in Patients With Class II Versus Class III and IV Heart Failure (from the InSync/InSync ICD Italian Registry)(dagger)(dagger)Conflicts of interest: …. Am. J. Cardiol. 2007:1007-1012. [pmid: 17826388].
Hernandez Madrid A, Escobar Cervantes C, Marin Marin I, Bernal Morell E. Cardiac resynchronization. Socioeconomic and health care impact. Mortality of procedure. Cost-benefit ratio. Impact on functional class/quality of life. Prognosis and follow-up: Resincronizacion cardiaca. Impacto socioeconomico sanitario. Mortalidad del procedimiento. Relacion coste-beneficio. Impacto en la clase funcional/calidad de vida. Pronostico y seguimiento. Invest. Cardiovasc. 2005:135-150.
Knuuti J, Sundell J, Naum A, Engblom E, Koistinen J, Ylitalo A, Stolen KQ, Kalliokoski R, Nekolla SG, Bax KEJJ, Airaksinen KEJ. Assessment of right ventricular oxidative metabolism by PET in patients with idiopathic dilated cardiomyopathy undergoing cardiac resynchronisation therapy. Eur. J. Nucl. Med. Mol. Imaging. 2004:1592-1598. [pmid: 15290120].
Ferreira Santos J, Caetano F, Parreira L, Madeira J, Cardoso P, Fonseca N, Segurado F, Neves Soares L, Ines L. Tissue Doppler Echocardiography for Evaluation of Patients with Ventricular Resynchronization Therapy: Ecocardiografia com Doppler Tecidular para Avaliacao de Doentes com Terapeutica de Ressincronizacao Ventricular. Rev. Port. Cardiol. 2003:1363-1371. [pmid: 14768491].
Ferreira Santos J, Caetano F, Parreira L, Madeira J, Cardoso P, Fonseca N, Segurado F, Neves Soares L, Ines L. Effects of Cardiac Resynchronization Therapy on Right Ventricular Function - Evaluation with Tissue Doppler Echocardiography: Efeitos da Terapeutica de Ressincronizacao Ventricular na Funcao Ventricular Direita - Avaliacao por Ecocardiografia com Doppler Tecidular. Rev. Port. Cardiol. 2003:1347-1355. [pmid: 14768490].
Chatterjee NA, Upadhyay GA, Singal G, Parks KA, Dec GW, Singh JP, Lewis GD. Pre-capillary pulmonary hypertension and right ventricular dilation predict clinical outcome in cardiac resynchronization therapy. JACC Heart Fail. 2014:230-237. [pmid: 24952689].
Kelli HM, Merchant FM, Mengistu A, Casey M, Hoskins M, El-Chami MF. Intermediate-term mortality and incidence of ICD therapy in octogenarians after cardiac resynchronization therapy. J Geriatr Cardiol. 2014:180-184. [pmid: 25278964].
Ruwald MH, Mittal S, Ruwald AC, Aktas MK, Daubert JP, McNitt S, Al-Ahmad A, Jons C, Kutyifa V, Steinberg JS, Wang P, Moss AJ, Zareba W. Association between frequency of atrial and ventricular ectopic beats and biventricular pacing percentage and outcomes in patients with cardiac resynchronization therapy. J Am Coll Cardiol. 2014:971-981. [pmid: 25190230].
Sherazi S, Goldenberg I, Moss AJ, Solomon S, Kutyifa V, McNitt S, Shah AH, Huang DT, Aktas MK, Zareba W, Barsheshet A. Comparison of Low Versus High (&gt;40 mm Hg) Pulse Pressure to Predict the Benefit of Cardiac Resynchronization Therapy for Heart Failure (from the Multicenter Automatic Defibrillator Implantation Trial-Cardiac Resynchronization Therapy Trial). Am J Cardiol. 2014:1053-1058. [pmid: 25118116].
Bajraktari G, Ronn F, Ibrahimi P, Jashari F, Lindmark K, Jensen SM, Henein MY. Combined electrical and global markers of dyssynchrony predict clinical response to Cardiac Resynchronization Therapy. Scand Cardiovasc J. 2014:304-310. [pmid: 25117854].
Wang J, Su Y, Bai J, Wang W, Qin S, Ge J. Elevated pulmonary artery pressure predicts poor outcome after cardiac resynchronization therapy. J Interv Card Electrophysiol. 2014:171-178. [pmid: 24728706].
Brouwers C, Versteeg H, Meine M, Heijnen CJ, Kavelaars AM, Pedersen SS, Mommersteeg PM. Association between brain natriuretic peptide, markers of inflammation and the objective and subjective response to cardiac resynchronization therapy. Brain Behav Immun. 2014:211-218. [pmid: 24704567].
Wilton SB, Exner DV, Healey JS, Birnie D, Arnold MO, Sapp JL, Thibault B, Simpson CS, Tung S, Crystal E, Sivakumaran S, Khaykin Y, Yetisir E, Wells G, Tang AS. Left ventricular lead position and outcomes in the Resynchronization-Defibrillation for Ambulatory Heart Failure Trial (RAFT). Can J Cardiol. 2014:413-419. [pmid: 24561009].
Bose A, Kandala J, Upadhyay GA, Riedl L, Ahmado I, Padmanabhan R, Gewirtz H, Mulligan LJ, Singh JP. Impact of myocardial viability and left ventricular lead location on clinical outcome in cardiac resynchronization therapy recipients with ischemic cardiomyopathy. J Cardiovasc Electrophysiol. 2014:507-513. [pmid: 24350650].
Rickard J, Cheng A, Spragg D, Cantillon D, Baranowski B, Varma N, Wilkoff BL, Tang WH. A clinical prediction rule to identify patients at heightened risk for early demise following cardiac resynchronization therapy. J Cardiovasc Electrophysiol. 2014:278-282. [pmid: 24320726].
Rickard J, Cheng A, Spragg D, Bansal S, Niebauer M, Baranowski B, Cantillon DJ, Tchou PJ, Grimm RA, Tang WH, Wilkoff BL, Varma N. Durability of the survival effect of cardiac resynchronization therapy by level of left ventricular functional improvement: fate of &quot;nonresponders&quot;. Heart Rhythm. 2014:412-416. [pmid: 24291412].
Bortnik M, Degiovanni A, Dell'era G, Cavallino C, Occhetta E, Marino P. Prevalence of ventricular arrhythmias in patients with cardiac resynchronization therapy without back-up ICD: a single-center experience. J Cardiovasc Med (Hagerstown). 2014:301-306. [pmid: 23811840].
Knackstedt C, Arndt M, Mischke K, Marx N, Nieman F, Kunert HJ, Schauerte P, Norra C. Depression, psychological distress, and quality of life in patients with cardioverter defibrillator with or without cardiac resynchronization therapy. Heart Vessels. 2014:364-374. [pmid: 23732755].

## Population inclusion criteria do not fall within the QRS>/=120ms and LVEF</=35% range

Rickard J, Tarakji K, Cheng A, Spragg D, Cantillon DJ, Martin DO, Baranowski B, Gordon SM, Tang WH, Kanj M, Wazni O, Wilkoff BL. Survival of patients with biventricular devices after device infection, extraction, and reimplantation. JACC Heart Fail. 2013:508-513. [pmid: 24622003].
Frigerio M, Lunati M, Pasqualucci D, Vargiu S, Foti G, Pedretti S, Vittori C, Cattafi G, Magenta G, Campo C, Bisetti S, Mercuro G. Left ventricular ejection fraction overcrossing 35% after one year of cardiac resynchronization therapy predicts long term survival and freedom from sudden cardiac death: Single center observational experience. Int J Cardiol. 2014:64-71. [pmid: 24456869].
Suleiman M, Goldenberg I, Haim M, Schliamser JE, Boulos M, Ilan M, Swissa M, Gavrielov-Yusim N, Fuchs T, Amit G, Glikson M. Clinical characteristics and outcomes of elderly patients treated with an implantable cardioverter-defibrillator or cardiac resynchronization therapy in a real-world setting: Data from the Israeli ICD Registry. Heart Rhythm. 2014:435-441. [pmid: 24315966].
Chang PC, Wo HT, Chen TH, Wu D, Lin FC, Wang CC. Remote Past Left Ventricular Function before Chronic Right Ventricular Pacing Predicts Responses to Cardiac Resynchronization Therapy Upgrade. Pacing Clin Electrophysiol. 2013.
Schaer BA, Hitz L, Sticherling C, Kuhne M, Dickenmann M, Jordaens M, Osswald L, Theuns S. Changes in renal function over time in patients with cardiac resynchronisation therapy. Swiss Med Wkly. 2013:w13863. [pmid: 24163096].
Gold MR, Daubert JC, Abraham WT, Hassager C, Dinerman JL, Hudnall JH, Cerkvenik J, Linde C. Implantable defibrillators improve survival in patients with mildly symptomatic heart failure receiving cardiac resynchronization therapy: analysis of the long-term follow-up of remodeling in systolic left ventricular dysfunction (REVERSE). Circ Arrhythm Electrophysiol. 2013:1163-1168. [pmid: 24125796].
Ruschitzka F, Abraham WT, Singh JP, Bax JJ, Borer JS, Brugada J, Dickstein K, Ford I, Gorcsan J 3rd, Gras D, Krum H, Sogaard P, Holzmeister J. Cardiac-resynchronization therapy in heart failure with a narrow QRS complex. N Engl J Med. 2013:1395-1405. [pmid: 23998714].
Peterson PN, Greiner MA, Qualls LG, Al-Khatib SM, Curtis JP, Fonarow GC, Hammill SC, Heidenreich PA, Hammill BG, Piccini JP, Hernandez AF, Curtis LH, Masoudi FA. QRS duration, bundle-branch block morphology, and outcomes among older patients with heart failure receiving cardiac resynchronization therapy. JAMA. 2013:617-626. [pmid: 23942680].
Mollo R, Cosenza A, Coviello I, Stazi A, Russo G, Villano A, Sestito A, Bencardino G, Lanza GA, Crea F. A novel electrocardiographic predictor of clinical response to cardiac resynchronization therapy. Europace. 2013:1615-1621. [pmid: 23794613].
Linde C, Gold MR, Abraham WT, St John Sutton M, Ghio S, Cerkvenik J, Daubert C. Long-term impact of cardiac resynchronization therapy in mild heart failure: 5-year results from the REsynchronization reVErses Remodeling in Systolic left vEntricular dysfunction (REVERSE) study. Eur Heart J. 2013:2592-2599. [pmid: 23641006].
Muto C, Solimene F, Gallo P, Nastasi M, La Rosa C, Calvanese R, Iengo R, Canciello M, Sangiuolo R, Diemberger I, Ciardiello C, Tuccillo B. A randomized study of cardiac resynchronization therapy defibrillator versus dual-chamber implantable cardioverter-defibrillator in ischemic cardiomyopathy with narrow QRS: the NARROW-CRT study. Circ Arrhythm Electrophysiol. 2013:538-545. [pmid: 23592833].
Wasmer K, Kobe J, Andresen D, Zahn R, Spitzer SG, Jehle J, Brachmann J, Stellbrink C, Martens E, Hochadel M, Senges J, Klein H, Eckardt L. Comparing outcome of patients with coronary artery disease and dilated cardiomyopathy in ICD and CRT recipients: data from the German DEVICE-registry. Clin Res Cardiol. 2013:513-521. [pmid: 23543113].
Pan W, Su Y, Zhu W, Shu X, Ge J. Notched QRS complex in lateral leads as a novel predictor of response to cardiac resynchronization therapy. Ann Noninvasive Electrocardiol. 2013:181-187. [pmid: 23530489].
Ahsan SY, Saberwal B, Lambiase PD, Chaubey S, Segal OR, Gopalamurugan AB, McCready J, Rogers DP, Lowe MD, Chow AW. An 8-year single-centre experience of cardiac resynchronisation therapy: procedural success, early and late complications, and left ventricular lead performance. Europace. 2013:711-717. [pmid: 23315159].
Arias MA, Pachon M, Puchol A, Jimenez-Lopez J, Rodriguez-Padial L. Acute and mid-term outcomes of transvenous implant of a new left ventricular quadripolar lead versus bipolar leads for cardiac resynchronization therapy: results from a single-center prospective database. Cardiol J. 2012:470-478. [pmid: 23042310].
Mathew J, Katz R, St John Sutton M, Dixit S, Gerstenfeld EP, Ghio S, Gold MR, Linde C, Shlipak MG, Deo R. Chronic kidney disease and cardiac remodelling in patients with mild heart failure: results from the REsynchronization reVErses Remodeling in Systolic Left vEntricular Dysfunction (REVERSE) study. Eur J Heart Fail. 2012:1420-1428. [pmid: 22956574].
Mandal S, Pande A, Mandal D, Kumar A, Sarkar A, Kahali D, Mazumdar B, Panja M. Permanent pacemaker-related upper extremity deep vein thrombosis: a series of 20 cases. Pacing Clin Electrophysiol. 2012:1194-1198. [pmid: 22816726].
Gold MR, Thebault C, Linde C, Abraham WT, Gerritse B, Ghio S, St John Sutton M, Daubert JC. Effect of QRS duration and morphology on cardiac resynchronization therapy outcomes in mild heart failure: results from the Resynchronization Reverses Remodeling in Systolic Left Ventricular Dysfunction (REVERSE) study. Circulation. 2012:822-829. [pmid: 22781424].
Hosoda J, Ishikawa T, Matsushita K, Matsumoto K, Kimura Y, Miyamoto M, Ogawa H, Takamura T, Sugano T, Ishigami T, Uchino K, Kimura K, Umemura S. Impact of renal insufficiency on long-term clinical outcome in patients with heart failure treated by cardiac resynchronization therapy. J Cardiol. 2012:301-305. [pmid: 22763383].
Ploux S, Whinnett Z, Lumens J, Denis A, Zemmoura A, De Guillebon M, Ramoul K, Ritter P, Jais P, Clementy J, Haissaguerre M, Bordachar P. Acute hemodynamic response to biventricular pacing in heart failure patients with narrow, moderately, and severely prolonged QRS duration. Heart Rhythm. 2012:1247-1250. [pmid: 22406382].
Donahue T, Niazi I, Leon A, Stucky M, Herrmann K. Acute and chronic response to CRT in narrow QRS patients. J Cardiovasc Transl Res. 2012:232-241. [pmid: 22207279].
Rickard J, Brennan DM, Martin DO, Hsich E, Tang WH, Lindsay BD, Starling RC, Wilkoff BL, Grimm RA. The impact of left ventricular size on response to cardiac resynchronization therapy. Am Heart J. 2011:646-653. [pmid: 21982656].
Albertsen AE, Mortensen PT, Jensen HK, Poulsen SH, Egeblad H, Nielsen JC. Adverse effect of right ventricular pacing prevented by biventricular pacing during long-term follow-up: a randomized comparison. Eur J Echocardiogr. 2011:767-772. [pmid: 21857020].
Lim P, Donal E, Lafitte S, Derumeaux G, Habib G, Reant P, Thivolet S, Lellouche N, Grimm RA, Gueret P. Multicentre study using strain delay index for predicting response to cardiac resynchronization therapy (MUSIC study). Eur J Heart Fail. 2011:984-991. [pmid: 21810831].
Rickard J, Zardkoohi O, Popovic Z, Verhaert D, Sraow D, Baranowski B, Martin DO, Grimm RA, Chung MK, Tchou P, Lindsay BA, Wilkoff BL. QRS fragmentation is not associated with poor response to cardiac resynchronization therapy. Ann Noninvasive Electrocardiol. 2011:165-171. [pmid: 21496167].
Enomoto K, Yamabe H, Toyama K, Matsuzawa Y, Yamamuro M, Uemura T, Morihisa K, Iwashita S, Kaikita K, Sugiyama S, Ogawa H. Improvement effect on endothelial function in patients with congestive heart failure treated with cardiac resynchronization therapy. J Cardiol. 2011:69-73. [pmid: 21493043].
Tompkins C, McLean R, Cheng A, Brinker JA, Marine JE, Nazarian S, Spragg DD, Sinha S, Halperin H, Tomaselli GF, Berger RD, Calkins H, Henrikson CA. End-stage renal disease predicts complications in pacemaker and ICD implants. J Cardiovasc Electrophysiol. 2011:1099-1104. [pmid: 21489029].
Wei S, Loyo-Berrios NI, Haigney MC, Cheng H, Pinnow EE, Mitchell KR, Beachy JH, Woodward AM, Wang Y, Curtis JP, Marinac-Dabic D. Elevated B-type natriuretic peptide is associated with increased in-hospital mortality or cardiac arrest in patients undergoing implantable cardioverter-defibrillator implantation. Circ Cardiovasc Qual Outcomes. 2011:346-354. [pmid: 21487093].
Rickard J, Popovic Z, Verhaert D, Sraow D, Baranowski B, Martin DO, Lindsay BD, Varma N, Tchou P, Grimm RA, Wilkoff BL, Chung MK. The QRS narrowing index predicts reverse left ventricular remodeling following cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2011:604-611. [pmid: 21276023].
Kapetanakis S, Bhan A, Murgatroyd F, Kearney MT, Gall N, Zhang Q, Yu CM, Monaghan MJ. Real-time 3D echo in patient selection for cardiac resynchronization therapy. JACC Cardiovasc Imaging. 2011:16-26. [pmid: 21232699].
Leyva F, Foley PW, Chalil S, Irwin N, Smith RE. Female gender is associated with a better outcome after cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2011:82-88. [pmid: 21214589].
Gold MR, Linde C, Abraham WT, Gardiwal A, Daubert JC. The impact of cardiac resynchronization therapy on the incidence of ventricular arrhythmias in mild heart failure. Heart Rhythm. 2011:679-684. [pmid: 21185401].
Linde C, Abraham WT, Gold MR, Daubert C. Cardiac resynchronization therapy in asymptomatic or mildly symptomatic heart failure patients in relation to etiology: results from the REVERSE (REsynchronization reVErses Remodeling in Systolic Left vEntricular Dysfunction) study. J Am Coll Cardiol. 2010:1826-1831. [pmid: 21087711].
Lin G, Gersh BJ, Greene EL, Redfield MM, Hayes DL, Brady PA. Renal function and mortality following cardiac resynchronization therapy. Eur Heart J. 2011:184-190. [pmid: 21068051].
van Bommel RJ, Borleffs CJ, Ypenburg C, Marsan NA, Delgado V, Bertini M, van der Wall EE, Schalij MJ, Bax JJ. Morbidity and mortality in heart failure patients treated with cardiac resynchronization therapy: influence of pre-implantation characteristics on long-term outcome. Eur Heart J. 2010:2783-2790. [pmid: 20693544].
van Bommel RJ, Gorcsan J 3rd, Chung ES, Abraham WT, Gjestvang FT, Leclercq C, Monaghan MJ, Nihoyannopoulos P, Peraldo C, Yu CM, Demas M, Gerritse B, Bax JJ. Effects of cardiac resynchronisation therapy in patients with heart failure having a narrow QRS Complex enrolled in PROSPECT. Heart. 2010:1107-1113. [pmid: 20610457].
Voigt A, Shalaby A, Adelstein E, Saba S. Beta-blocker utilization and outcomes in patients receiving cardiac resynchronization therapy. Clin Cardiol. 2010:E1-E5. [pmid: 20549778].
Rafique AM, Thomas Peter C, Naqvi TZ. A revised approach to patient selection for cardiac resynchronization treatment using multiple asynchrony parameters in Narrow- and Wide-QRS cardiomyopathy causes cardiac reverse remodelling: a single centre non-randomized prospective study. Europace. 2010:1127-1135. [pmid: 20466819].
Rickard J, Kumbhani DJ, Popovic Z, Verhaert D, Manne M, Sraow D, Baranowski B, Martin DO, Lindsay BD, Grimm RA, Wilkoff BL, Tchou P. Characterization of super-response to cardiac resynchronization therapy. Heart Rhythm. 2010:885-889. [pmid: 20382271].
Frohlich G, Steffel J, Hurlimann D, Enseleit F, Luscher TF, Ruschitzka F, Abraham WT, Holzmeister J. Upgrading to resynchronization therapy after chronic right ventricular pacing improves left ventricular remodelling. Eur Heart J. 2010:1477-1485. [pmid: 20233792].
Rickard J, Kumbhani DJ, Gorodeski EZ, Baranowski B, Wazni O, Martin DO, Grimm R, Wilkoff BL. Cardiac resynchronization therapy in non-left bundle branch block morphologies. Pacing Clin Electrophysiol. 2010:590-595. [pmid: 20025703].
Antonio N, Lourenco C, Teixeira R, Saraiva F, Coelho L, Ventura M, Cristovao J, Elvas L, Goncalves L, Providencia LA. Cardiac resynchronization therapy is effective even in elderly patients with comorbidities. J Interv Card Electrophysiol. 2010:61-68. [pmid: 19937373].
D'Andrea A, Scarafile R, Riegler L, Salerno G, Gravino R, Cocchia R, Castaldo F, Allocca F, Limongelli G, Di Salvo G, Cuomo S, Pacileo G, Caso P, Russo MG, Calabro R. Right atrial size and deformation in patients with dilated cardiomyopathy undergoing cardiac resynchronization therapy. Eur J Heart Fail. 2009:1169-1177. [pmid: 19926601].
Boriani G, Rapezzi C, Diemberger I, Gonzini L, Gorini M, Lucci D, Sinagra G, Cooke RM, Di Pasquale G, Tavazzi L, Maggioni AP. Trial-generated profiles for implantation of electrical devices in outpatients with heart failure: real-world prevalence and 1-year outcome. J Eval Clin Pract. 2010:82-91. [pmid: 19874436].
St John Sutton M, Ghio S, Plappert T, Tavazzi L, Scelsi L, Daubert C, Abraham WT, Gold MR, Hassager C, Herre JM, Linde C. Cardiac resynchronization induces major structural and functional reverse remodeling in patients with New York Heart Association class I/II heart failure. Circulation. 2009:1858-1865. [pmid: 19858419].
El-Saed A, Voigt A, Shalaby A. Usefulness of brain natriuretic peptide level at implant in predicting mortality in patients with advanced but stable heart failure receiving cardiac resynchronization therapy. Clin Cardiol. 2009:E33-E38. [pmid: 19816874].
Pfau G, Schilling T, Kozian A, Lux A, Gotte A, Huth C, Hachenberg T. Outcome after implantation of cardiac resynchronization/defibrillation systems in patients with congestive heart failure and left bundle-branch block. J Cardiothorac Vasc Anesth. 2010:30-36. [pmid: 19800818].
Daubert C, Gold MR, Abraham WT, Ghio S, Hassager C, Goode G, Szili-Torok T, Linde C. Prevention of disease progression by cardiac resynchronization therapy in patients with asymptomatic or mildly symptomatic left ventricular dysfunction: insights from the European cohort of the REVERSE (Resynchronization Reverses Remodeling in Systolic Left Ventricular Dysfunction) trial. J Am Coll Cardiol. 2009:1837-1846. [pmid: 19800193].
Dickstein K, Bogale N, Priori S, Auricchio A, Cleland JG, Gitt A, Limbourg T, Linde C, van Veldhuisen DJ, Brugada J. The European cardiac resynchronization therapy survey. Eur Heart J. 2009:2450-2460. [pmid: 19723694].
Caldwell JC, Contractor H, Petkar S, Ali R, Clarke B, Garratt CJ, Neyses L, Mamas MA. Atrial fibrillation is under-recognized in chronic heart failure: insights from a heart failure cohort treated with cardiac resynchronization therapy. Europace. 2009:1295-1300. [pmid: 19648586].
Kamireddy S, Agarwal SK, Adelstein E, Jain S, Saba S. Correlation of electrical and mechanical reverse remodeling after cardiac resynchronization therapy. Ann Noninvasive Electrocardiol. 2009:153-157. [pmid: 19419400].
Nordbeck P, Seidl B, Fey B, Bauer WR, Ritter O. Effect of cardiac resynchronization therapy on the incidence of electrical storm. Int J Cardiol. 2010:330-336. [pmid: 19359057].
Markowitz SM, Lewen JM, Wiggenhorn CJ, Abraham WT, Stein KM, Iwai S, Lerman BB. Relationship of reverse anatomical remodeling and ventricular arrhythmias after cardiac resynchronization. J Cardiovasc Electrophysiol. 2009:293-298. [pmid: 19175852].
Hansky B, Vogt J, Zittermann A, Guldner H, Heintze J, Schulz U, Horstkotte D, Tenderich G, Korfer R. Cardiac resynchronization therapy: long-term alternative to cardiac transplantation?. Ann Thorac Surg. 2009:432-438. [pmid: 19161754].
Alper AT, Akyol A, Hasdemir H, Yildirim A, Nurkalem Z, Guvenc TS, Cakmak N, Oguz E, Erdinler IC, Gurkan K. Effect of cardiac resynchronization therapy on mean platelet volume. Acta Cardiol. 2008:735-739. [pmid: 19157169].
Tanaka Y, Tada H, Yamashita E, Sato C, Irie T, Hori Y, Goto K, Iwamoto J, Manni H, Yokokawa M, Naito S, Oshima S, Taniguchi K. Change in blood pressure just after initiation of cardiac resynchronization therapy predicts long-term clinical outcome in patients with advanced heart failure. Circ J. 2009:288-294. [pmid: 19110507].
Soliman OI, van Dalen BM, Nemes A, Zwaan HB, Vletter WB, ten Cate FJ, Theuns DA, Jordaens LJ, Geleijnse ML. Quantification of left ventricular systolic dyssynchrony by real-time three-dimensional echocardiography. J Am Soc Echocardiogr. 2009:232-239. [pmid: 19101112].
Wiesbauer F, Baytaroglu C, Azar D, Blessberger H, Goliasch G, Graf S, Mundigler G, Pacher R, Maurer G, Binder T. Echo Doppler parameters predict response to cardiac resynchronization therapy. Eur J Clin Invest. 2009:1-10. [pmid: 19087125].
Nazeri A, Massumi A, Rasekh A, Saeed M, Frank C, Wilson JM, Lopez JA, Razavi M. Cardiac resynchronization therapy may improve symptoms of congestive heart failure in patients without electrical or mechanical dyssynchrony. Europace. 2009:86-88. [pmid: 19056743].
Linde C, Abraham WT, Gold MR, St John Sutton M, Ghio S, Daubert C. Randomized trial of cardiac resynchronization in mildly symptomatic heart failure patients and in asymptomatic patients with left ventricular dysfunction and previous heart failure symptoms. J Am Coll Cardiol. 2008:1834-1843. [pmid: 19038680].
Perego GB, Landolina M, Vergara G, Lunati M, Zanotto G, Pappone A, Lonardi G, Speca G, Iacopino S, Varbaro A, Sarkar S, Hettrick DA, Denaro A. Implantable CRT device diagnostics identify patients with increased risk for heart failure hospitalization. J Interv Card Electrophysiol. 2008:235-242. [pmid: 18810621].
Buck S, Maass AH, Nieuwland W, Anthonio RL, Van Veldhuisen DJ, Van Gelder IC. Impact of interventricular lead distance and the decrease in septal-to-lateral delay on response to cardiac resynchronization therapy. Europace. 2008:1313-1319. [pmid: 18694907].
Swindle J, Burroughs TE, Schnitzler MA, Hauptman PJ. Short-term mortality and cost associated with cardiac device implantation in patients hospitalized with heart failure. Am Heart J. 2008:322-328. [pmid: 18657663].
Zhang Q, Fung JW, Chan JY, Yip G, Lam YY, Liang YJ, Yu CM. Difference in long-term clinical outcome after cardiac resynchronisation therapy between ischaemic and non-ischaemic aetiologies of heart failure. Heart. 2009:113-118. [pmid: 18653570].
Kronborg MB, Mortensen PT, Kirkfeldt RE, Nielsen JC. Very long term follow-up of cardiac resynchronization therapy: clinical outcome and predictors of mortality. Eur J Heart Fail. 2008:796-801. [pmid: 18619900].
Becker M, Erdmann N, Stegemann E, Benke D, Schauerte PN, Schaefer WM, Autschbach R, Kelm M, Koch KC. Survival and quality of life in patients with cardiac resynchronization therapy for severe heart failure and in heart transplant recipients within a contemporary heart failure management program. J Heart Lung Transplant. 2008:746-752. [pmid: 18582804].
Zanon F, Aggio S, Baracca E, Pastore G, Corbucci G, Boaretto G, Braggion G, Piergentili C, Rigatelli G, Roncon L. Ventricular-arterial coupling in patients with heart failure treated with cardiac resynchronization therapy: may we predict the long-term clinical response?. Eur J Echocardiogr. 2009:106-111. [pmid: 18579495].
Sweeney MO, Hellkamp AS, Ellenbogen KA, Lamas GA. Reduced ejection fraction, sudden cardiac death, and heart failure death in the mode selection trial (MOST): implications for device selection in elderly patients with sinus node disease. J Cardiovasc Electrophysiol. 2008:1160-1166. [pmid: 18554201].
Faran A, Dabrowska-Kugacka A, Lewicka-Nowak E, Tybura S, Zieba B, Danilowicz-Szymanowicz L, Krzyminska-Stasiuk E, Kempa M, Kogut K, Raczak G. Echocardiographic evaluation of patients with severe heart failure and impairment of intraventricular conduction following cardiac resynchronisation therapy. Kardiol Pol. 2008:396-403. discussion 404-5. [pmid: 18473268].
Fung JW, Yip GW, Zhang Q, Fang F, Chan JY, Li CM, Wu LW, Chan GC, Chan HC, Yu CM. Improvement of left atrial function is associated with lower incidence of atrial fibrillation and mortality after cardiac resynchronization therapy. Heart Rhythm. 2008:780-786. [pmid: 18467188].
Shalaby A, El-Saed A, Voigt A, Albany C, Saba S. Elevated serum creatinine at baseline predicts poor outcome in patients receiving cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2008:575-579. [pmid: 18439171].
Goscinska-Bis K, Bis J, Krejca M, Ulczok R, Szmagala P, Bochenek A, Kargul W. Totally epicardial cardiac resynchronization therapy system implantation in patients with heart failure undergoing CABG. Eur J Heart Fail. 2008:498-506. [pmid: 18413295].
Silva RT, Martinelli Filho M, Lima CE, Martins DG, Nishioka SA, Pedrosa AA, Crevelari ES, Costa R, Sosa EA, Ramires JA. Functional behavior of patients with conventional pacemakers undergoing cardiac resynchronization. Arq Bras Cardiol. 2008:138-143. [pmid: 18392387].
Delnoy PP, Ottervanger JP, Luttikhuis HO, Elvan A, Misier AR, Beukema WP, van Hemel NM. Clinical response of cardiac resynchronization therapy in the elderly. Am Heart J. 2008:746-751. [pmid: 18371486].
Nayak HM, Verdino RJ, Russo AM, Gerstenfeld EP, Hsia HH, Lin D, Dixit S, Cooper JM, Callans DJ, Marchlinski FE. Ventricular tachycardia storm after initiation of biventricular pacing: incidence, clinical characteristics, management, and outcome. J Cardiovasc Electrophysiol. 2008:708-715. [pmid: 18363690].
Cazeau SJ, Daubert JC, Tavazzi L, Frohlig G, Paul V. Responders to cardiac resynchronization therapy with narrow or intermediate QRS complexes identified by simple echocardiographic indices of dyssynchrony: the DESIRE study. Eur J Heart Fail. 2008:273-280. [pmid: 18314381].
Milliez P, Thomas O, Haggui A, Schurando P, Squara P, Cohen-Solal A, Mebazaa A, Leenhardt A. Cardiac resynchronisation as a rescue therapy in patients with catecholamine-dependent overt heart failure: results from a short and mid-term study. Eur J Heart Fail. 2008:291-297. [pmid: 18313982].
Novak M, Lipoldova J, Kamaryt P, Dvorak J Jr, Ozabalova E, Vank P, Hude P, Krejci J. Cardiac resynchronization therapy. Midterm follow-up of 128 patients. Bratisl Lek Listy. 2007:445-452. [pmid: 18306724].
Iler MA, Hu T, Ayyagari S, Callahan TD 4th, Civello KC, Thal SG, Wilkoff BL, Chung MK. Prognostic value of electrocardiographic measurements before and after cardiac resynchronization device implantation in patients with heart failure due to ischemic or nonischemic cardiomyopathy. Am J Cardiol. 2008:359-363. [pmid: 18237600].
Muxi A, Paredes P, Mont L, Setoain FJ, Duch J, Fuertes S, Ortin J, Diaz-Infante E, Pons F. Left ventricular function and visual phase analysis with equilibrium radionuclide angiography in patients with biventricular device. Eur J Nucl Med Mol Imaging. 2008:912-921. [pmid: 18228016].
Inage T, Yoshida T, Hiraki T, Ohe M, Takeuchi T, Nagamoto Y, Fukuda Y, Gondo T, Imaizumi T. Chronic cardiac resynchronization therapy reverses cardiac remodelling and improves invasive haemodynamics of patients with severe heart failure on optimal medical treatment. Europace. 2008:379-383. [pmid: 18227354].
Achilli A, Sassara M, Pontillo D, Turreni F, Rossi P, De Luca R, Klersy C, Patruno N, Achilli P, Sallusti L, Spadaccia P, Cricco L, Serra F. Effectiveness of cardiac resynchronisation therapy in patients with echocardiographic evidence of mechanical dyssynchrony. J Cardiovasc Med (Hagerstown). 2008:131-136. [pmid: 18192804].
Schiffer AA, Denollet J, Pedersen SS, Broers H, Widdershoven JW. Health status in patients treated with cardiac resynchronization therapy: modulating effects of personality. Pacing Clin Electrophysiol. 2008:28-37. [pmid: 18181907].
Becker M, Hoffmann R, Schmitz F, Hundemer A, Kuhl H, Schauerte P, Kelm M, Franke A. Relation of optimal lead positioning as defined by three-dimensional echocardiography to long-term benefit of cardiac resynchronization. Am J Cardiol. 2007:1671-1676. [pmid: 18036367].
Stollberger C, Blazek G, Bucher E, Finsterer J. Cardiac resynchronization therapy in left ventricular hypertrabeculation/non-compaction and myopathy. Europace. 2008:59-62. [pmid: 18029382].
Nof E, Gurevitz O, Carraso S, Bar-Lev D, Luria D, Bachar S, Eldar M, Glikson M. Comparison of results with different left ventricular pacing leads. Europace. 2008:35-39. [pmid: 18003633].
Varma N, Jia P, Rudy Y. Electrocardiographic imaging of patients with heart failure with left bundle branch block and response to cardiac resynchronization therapy. J Electrocardiol. 2007:S174-S178. [pmid: 17993318].
Gradaus R, Stuckenborg V, Loher A, Kobe J, Reinke F, Gunia S, Vahlhaus C, Breithardt G, Bruch C. Diastolic filling pattern and left ventricular diameter predict response and prognosis after cardiac resynchronisation therapy. Heart. 2008:1026-1031. [pmid: 17984216].
Lilli A, Ricciardi G, Porciani MC, Perini AP, Pieragnoli P, Musilli N, Colella A, Del Pace S, Michelucci A, Turreni F, Sassara M, Achilli A, Barold SS, Padeletti L. Cardiac resynchronization therapy: gender related differences in left ventricular reverse remodeling. Pacing Clin Electrophysiol. 2007:1349-1355. [pmid: 17976098].
Rosman J, Dhillon S, Mayer A, Hanon S, Paul S. Non-ischemic cardiomyopathy patients derive superior mortality benefit from cardiac resynchronization therapy. Indian Pacing Electrophysiol J. 2007:215-217. [pmid: 17957269].
Yu CM, Fang F, Zhang Q, Yip GW, Li CM, Chan JY, Wu L, Fung JW. Improvement of atrial function and atrial reverse remodeling after cardiac resynchronization therapy for heart failure. J Am Coll Cardiol. 2007:778-785. [pmid: 17707183].
Adelstein EC, Saba S. Burden of atrial fibrillation after cardiac resynchronization therapy. Am J Cardiol. 2007:268-272. [pmid: 17631081].
Diaz-Infante E, Sitges M, Vidal B, Mont L, Delgado V, Marigliano A, Macias A, Tolosana JM, Tamborero D, Azqueta M, Roig E, Pare C, Brugada J. Usefulness of ventricular dyssynchrony measured using M-mode echocardiography to predict response to resynchronization therapy. Am J Cardiol. 2007:84-89. [pmid: 17599446].
van Eck JW, van Hemel NM, Zuithof P, van Asseldonk JP, Voskuil TL, Grobbee DE, Moons KG. Incidence and predictors of in-hospital events after first implantation of pacemakers. Europace. 2007:884-889. [pmid: 17556376].
Wasserman K, Sun XG, Hansen JE. Effect of biventricular pacing on the exercise pathophysiology of heart failure. Chest. 2007:250-261. [pmid: 17505041].
Page E, Cazeau S, Ritter P, Galley D, Casset C. Physiological approach to monitor patients in congestive heart failure: application of a new implantable device-based system to monitor daily life activity and ventilation. Europace. 2007:687-693. [pmid: 17478462].
de Teresa E, Gomez-Doblas JJ, Lamas G, Alzueta J, Fernandez-Lozano I, Cobo E, Navarro X, Navarro-Lopez F, Stockburger M. Preventing ventricular dysfunction in pacemaker patients without advanced heart failure: rationale and design of the PREVENT-HF study. Europace. 2007:442-446. [pmid: 17460018].
Nagele H, Azizi M, Castel MA. Hemodynamic changes during cardiac resynchronization therapy. Clin Cardiol. 2007:141-143. [pmid: 17385702].
Ng K, Kedia N, Martin D, Tchou P, Natale A, Wilkoff B, Starling R, Grimm RA. The benefits of biventricular pacing in heart failure patients with narrow QRS, NYHA class II and right ventricular pacing. Pacing Clin Electrophysiol. 2007:193-198. [pmid: 17338715].
Hoppe UC, Freemantle N, Cleland JG, Marijianowski M, Erdmann E. Effect of cardiac resynchronization on morbidity and mortality of diabetic patients with severe heart failure. Diabetes Care. 2007:722-724. [pmid: 17327349].
Van de Veire NR, Bleeker GB, De Sutter J, Ypenburg C, Holman ER, van der Wall EE, Schalij MJ, Bax JJ. Tissue synchronisation imaging accurately measures left ventricular dyssynchrony and predicts response to cardiac resynchronisation therapy. Heart. 2007:1034-1039. [pmid: 17309912].
Gilliam FR 3rd, Kaplan AJ, Black J, Chase KJ, Mullin CM. Changes in heart rate variability, quality of life, and activity in cardiac resynchronization therapy patients: results of the HF-HRV registry. Pacing Clin Electrophysiol. 2007:56-64. [pmid: 17241316].
Hirschl DA, Jain VR, Spindola-Franco H, Gross JN, Haramati LB. Prevalence and characterization of asymptomatic pacemaker and ICD lead perforation on CT. Pacing Clin Electrophysiol. 2007:28-32. [pmid: 17241311].
Nagele H, Hashagen S, Azizi M, Behrens S, Castel MA. Long-term hemodynamic benefit of biventricular pacing depending on coronary sinus lead position. Herzschrittmacherther Elektrophysiol. 2006:185-190. [pmid: 17211748].
Achilli A, Peraldo C, Sassara M, Orazi S, Bianchi S, Laurenzi F, Donati R, Perego GB, Spampinato A, Valsecchi S, Denaro A, Puglisi A. Prediction of response to cardiac resynchronization therapy: the selection of candidates for CRT (SCART) study. Pacing Clin Electrophysiol. 2006:S11-S19. [pmid: 17169127].
Bai R, Yang XY, Song Y, Lin L, Lu JG, Ching CK, Pu J, Kam R, Hsu LF, Zhang CT, Teo WS, Wang L. Impact of left ventricular epicardial and biventricular pacing on ventricular repolarization in normal-heart individuals and patients with congestive heart failure. Europace. 2006:1002-1010. [pmid: 17043073].
Yu CM, Zhang Q, Yip GW, Chan YS, Lee PW, Wu LW, Lam YY, Kum LC, Chan HC, Chan S, Fung JW. Are left ventricular diastolic function and diastolic asynchrony important determinants of response to cardiac resynchronization therapy?. Am J Cardiol. 2006:1083-1087. [pmid: 17027576].
van Campen CM, Visser FC, van der Weerdt AP, Knaapen P, Comans EF, Lammertsma AA, de Cock CC, Visser CA. FDG PET as a predictor of response to resynchronisation therapy in patients with ischaemic cardiomyopathy. Eur J Nucl Med Mol Imaging. 2007:309-315. [pmid: 17021810].
Fung JW, Zhang Q, Yip GW, Chan JY, Chan HC, Yu CM. Effect of cardiac resynchronization therapy in patients with moderate left ventricular systolic dysfunction and wide QRS complex: a prospective study. J Cardiovasc Electrophysiol. 2006:1288-1292. [pmid: 16987381].
Boriani G, Gasparini M, Lunati M, Santini M, Landolina M, Vincenti A, Curnis A, Bocchiardo M, Padeletti L, Biffi M, Allaria L, Denaro A. Characteristics of ventricular tachyarrhythmias occurring in ischemic versus nonischemic patients implanted with a biventricular cardioverter-defibrillator for primary or secondary prevention of sudden death. Am Heart J. 2006:527.e1-527.e11. [pmid: 16923425].
Marai I, Gurevitz O, Carasso S, Nof E, Bar-Lev D, Luria D, Arbel Y, Freimark D, Feinberg MS, Eldar M, Glikson M. Improvement of congestive heart failure by upgrading of conventional to resynchronization pacemakers. Pacing Clin Electrophysiol. 2006:880-884. [pmid: 16923005].
Arzola-Castaner D, Taub C, Kevin Heist E, Fan D, Haelewyn K, Mela T, Picard MH, Ruskin JN, Singh JP. Left ventricular lead proximity to an akinetic segment and impact on outcome of cardiac resynchronization therapy. J Cardiovasc Electrophysiol. 2006:623-627. [pmid: 16836711].
Tedrow UB, Kramer DB, Stevenson LW, Stevenson WG, Baughman KL, Epstein LM, Lewis EF. Relation of right ventricular peak systolic pressure to major adverse events in patients undergoing cardiac resynchronization therapy. Am J Cardiol. 2006:1737-1740. [pmid: 16765124].
Kindermann M, Hennen B, Jung J, Geisel J, Bohm M, Frohlig G. Biventricular versus conventional right ventricular stimulation for patients with standard pacing indication and left ventricular dysfunction: the Homburg Biventricular Pacing Evaluation (HOBIPACE). J Am Coll Cardiol. 2006:1927-1937. [pmid: 16697307].
Zhang Q, Fung JW, Auricchio A, Chan JY, Kum LC, Wu LW, Yu CM. Differential change in left ventricular mass and regional wall thickness after cardiac resynchronization therapy for heart failure. Eur Heart J. 2006:1423-1430. [pmid: 16682380].
Yu CM, Zhang Q, Chan YS, Chan CK, Yip GW, Kum LC, Wu EB, Lee PW, Lam YY, Chan S, Fung JW. Tissue Doppler velocity is superior to displacement and strain mapping in predicting left ventricular reverse remodelling response after cardiac resynchronisation therapy. Heart. 2006:1452-1456. [pmid: 16621873].
Pires LA, Abraham WT, Young JB, Johnson KM. Clinical predictors and timing of New York Heart Association class improvement with cardiac resynchronization therapy in patients with advanced chronic heart failure: results from the Multicenter InSync Randomized Clinical Evaluation (MIRACLE) and Multicenter InSync ICD Randomized Clinical Evaluation (MIRACLE-ICD) trials. Am Heart J. 2006:837-843. [pmid: 16569543].
Da Costa A, Thevenin J, Roche F, Faure E, Romeyer-Bouchard C, Messier M, Convert G, Barthelemy JC, Isaaz K. Prospective validation of stress echocardiography as an identifier of cardiac resynchronization therapy responders. Heart Rhythm. 2006:406-413. [pmid: 16567286].
Vanderheyden M, Wellens F, Bartunek J, Verstreken S, Walraevens M, Geelen P, De Proft M, Goethals M. Cardiac resynchronization therapy delays heart transplantation in patients with end-stage heart failure and mechanical dyssynchrony. J Heart Lung Transplant. 2006:447-453. [pmid: 16563976].
Mangiavacchi M, Gasparini M, Faletra F, Klersy C, Morenghi E, Galimberti P, Genovese L, Regoli F, De Chiara F, Bragato R, Andreuzzi B, Pini D, Gronda E. Clinical predictors of marked improvement in left ventricular performance after cardiac resynchronization therapy in patients with chronic heart failure. Am Heart J. 2006:477.e1-477.e6. [pmid: 16442917].
de Sisti A, Toussaint JF, Lavergne T, Ollitrault J, Abergel E, Paziaud O, Ait Said M, Sader R, LE Heuzey JY, Guize L. Determinants of mortality in patients undergoing cardiac resynchronization therapy: baseline clinical, echocardiographic, and angioscintigraphic evaluation prior to resynchronization. Pacing Clin Electrophysiol. 2005:1260-1270. [pmid: 16403157].
Cozma D, Kalifa J, Pescariu S, Lighezan D, Deharo JC, Mornos C, Djiane P, Luca CT, Petrescu L, Dragulescu SI. Global myocardial index in patients with multisite pacing. Rom J Intern Med. 2004:521-531. [pmid: 16366129].
Doshi RN, Daoud EG, Fellows C, Turk K, Duran A, Hamdan MH, Pires LA. Left ventricular-based cardiac stimulation post AV nodal ablation evaluation (the PAVE study). J Cardiovasc Electrophysiol. 2005:1160-1165. [pmid: 16302897].
Ritter O, Koller ML, Fey B, Seidel B, Krein A, Langenfeld H, Bauer WR. Progression of heart failure in right univentricular pacing compared to biventricular pacing. Int J Cardiol. 2006:359-365. [pmid: 16297471].
Malfatto G, Facchini M, Branzi G, Brambilla R, Fratianni G, Tortorici E, Balla E, Perego GB. Reverse ventricular remodeling and improved functional capacity after ventricular resynchronization in advanced heart failure. Ital Heart J. 2005:578-583. [pmid: 16274020].
Fung JW, Yu CM, Chan JY, Chan HC, Yip GW, Zhang Q, Sanderson JE. Effects of cardiac resynchronization therapy on incidence of atrial fibrillation in patients with poor left ventricular systolic function. Am J Cardiol. 2005:728-731. [pmid: 16125504].
Albertsen AE, Nielsen JC, Pedersen AK, Hansen PS, Jensen HK, Mortensen PT. Left ventricular lead performance in cardiac resynchronization therapy: impact of lead localization and complications. Pacing Clin Electrophysiol. 2005:483-488. [pmid: 15955178].
Bomma C, Dalal D, Tandri H, Prakasa K, Nasir K, Roguin A, Tichnell C, James C, Lima JA, Calkins H, Bluemke DA. Regional differences in systolic and diastolic function in arrhythmogenic right ventricular dysplasia/cardiomyopathy using magnetic resonance imaging. Am J Cardiol. 2005:1507-1511. [pmid: 15950585].
Diaz-Infante E, Mont L, Leal J, Garcia-Bolao I, Fernandez-Lozano I, Hernandez-Madrid A, Perez-Castellano N, Sitges M, Pavon-Jimenez R, Barba J, Cavero MA, Moya JL, Perez-Isla L, Brugada J. Predictors of lack of response to resynchronization therapy. Am J Cardiol. 2005:1436-1440. [pmid: 15950566].
Yu CM, Fung JW, Zhang Q, Chan CK, Chan I, Chan YS, Kong SL, Sanderson JE, Lam CW. Improvement of serum NT-ProBNP predicts improvement in cardiac function and favorable prognosis after cardiac resynchronization therapy for heart failure. J Card Fail. 2005:S42-S46. [pmid: 15948100].
Boriani G, Biffi M, Martignani C, Ziacchi M, Saporito D, Grigioni F, Domenichini G, Valzania C, Diemberger I, Bertini M, Specchia S, Branzi A. Electrocardiographic remodeling during cardiac resynchronization therapy. Int J Cardiol. 2006:165-170. [pmid: 15923048].
Cowburn PJ, Patel H, Pipes RR, Parker JD. Contrast nephropathy post cardiac resynchronization therapy: an under-recognized complication with important morbidity. Eur J Heart Fail. 2005:899-903. [pmid: 15919239].
Salukhe TV, Francis DP, Clague JR, Sutton R, Poole-Wilson P, Henein MY. Chronic heart failure patients with restrictive LV filling pattern have significantly less benefit from cardiac resynchronization therapy than patients with late LV filling pattern. Int J Cardiol. 2005:5-12. [pmid: 15820279].
Aranda JM Jr, Woo GW, Conti JB, Schofield RS, Conti CR, Hill JA. Use of cardiac resynchronization therapy to optimize beta-blocker therapy in patients with heart failure and prolonged QRS duration. Am J Cardiol. 2005:889-891. [pmid: 15781026].
Cowburn PJ, Patel H, Jolliffe RE, Wald RW, Parker JD. Cardiac resynchronization therapy: an option for inotrope-supported patients with end-stage heart failure?. Eur J Heart Fail. 2005:215-217. [pmid: 15701469].
Bleeker GB, Schalij MJ, Molhoek SG, Holman ER, Verwey HF, Steendijk P, van der Wall EE, Bax JJ. Frequency of left ventricular dyssynchrony in patients with heart failure and a narrow QRS complex. Am J Cardiol. 2005:140-142. [pmid: 15619414].
Bordachar P, Lafitte S, Reuter S, Garrigue S, Sanders P, Roudaut R, Jais P, Haissaguerre M, Clementy J. Biventricular pacing and left ventricular pacing in heart failure: similar hemodynamic improvement despite marked electromechanical differences. J Cardiovasc Electrophysiol. 2004:1342-1347. [pmid: 15610275].
Bordachar P, Lafitte S, Reuter S, Sanders P, Jais P, Haissaguerre M, Roudaut R, Garrigue S, Clementy J. Echocardiographic parameters of ventricular dyssynchrony validation in patients with heart failure using sequential biventricular pacing. J Am Coll Cardiol. 2004:2157-2165. [pmid: 15582313].
Leclercq C, Gras D, Tang A, Alonso C, Thomas-Revault d'Allones F, Mabo P. Comparative effects of ventricular resynchronization therapy in heart failure patients with or without coronary artery disease. Ann Cardiol Angeiol (Paris). 2004:171-176. [pmid: 15369312].
Yu CM, Fung JW, Chan CK, Chan YS, Zhang Q, Lin H, Yip GW, Kum LC, Kong SL, Zhang Y, Sanderson JE. Comparison of efficacy of reverse remodeling and clinical improvement for relatively narrow and wide QRS complexes after cardiac resynchronization therapy for heart failure. J Cardiovasc Electrophysiol. 2004:1058-1065. [pmid: 15363081].
Turner MS, Bleasdale RA, Vinereanu D, Mumford CE, Paul V, Fraser AG, Frenneaux MP. Electrical and mechanical components of dyssynchrony in heart failure patients with normal QRS duration and left bundle-branch block: impact of left and biventricular pacing. Circulation. 2004:2544-2549. [pmid: 15148267].
Achilli A, Sassara M, Ficili S, Pontillo D, Achilli P, Alessi C, De Spirito S, Guerra R, Patruno N, Serra F. Long-term effectiveness of cardiac resynchronization therapy in patients with refractory heart failure and &quot;narrow&quot; QRS. J Am Coll Cardiol. 2003:2117-2124. [pmid: 14680737].
Toussaint JF, Lavergne T, Kerrou K, Froissart M, Ollitrault J, Darondel JM, Alonso C, Diebold B, Le Heuzey JY, Guize L, Paillard M. Basal asynchrony and resynchronization with biventricular pacing predict long-term improvement of LV function in heart failure patients. Pacing Clin Electrophysiol. 2003:1815-1823. [pmid: 12930495].
Adamson PB, Kleckner KJ, VanHout WL, Srinivasan S, Abraham WT. Cardiac resynchronization therapy improves heart rate variability in patients with symptomatic heart failure. Circulation. 2003:266-269. [pmid: 12860899].
Thackray SD, Witte KK, Nikitin NP, Clark AL, Kaye GC, Cleland JG. The prevalence of heart failure and asymptomatic left ventricular systolic dysfunction in a typical regional pacemaker population. Eur Heart J. 2003:1143-1152. [pmid: 12804929].
Alonso C, Ritter P, Leclercq C, Mabo P, Bailleul C, Daubert JC. Effects of cardiac resynchronization therapy on heart rate variability in patients with chronic systolic heart failure and intraventricular conduction delay. Am J Cardiol. 2003:1144-1147. [pmid: 12714168].
Gasparini M, Mantica M, Galimberti P, Genovese L, Pini D, Faletra F, Marchesina UL, Mangiavacchi M, Klersy C, Gronda E. Is the outcome of cardiac resynchronization therapy related to the underlying etiology?. Pacing Clin Electrophysiol. 2003:175-180. [pmid: 12687807].
Gasparini M, Mantica M, Galimberti P, Marconi M, Genovese L, Faletra F, Simonini S, Klersy C, Coates R, Gronda E. Beneficial effects of biventricular pacing in patients with a &quot;narrow&quot; QRS. Pacing Clin Electrophysiol. 2003:169-174. [pmid: 12687806].
Galizio NO, Pesce R, Valero E, Gonzalez JL, Favaloro RR, Favaloro L, Perrone S, Davila P, Godoy M. Which patients with congestive heart failure may benefit from biventricular pacing?. Pacing Clin Electrophysiol. 2003:158-161. [pmid: 12687804].
Erdogan A, Rueckleben S, Tillmanns HH, Waldecker B. Proportion of candidates for cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2003:152-154. [pmid: 12687802].
Cazeau S, Bordachar P, Jauvert G, Lazarus A, Alonso C, Vandrell MC, Mugica J, Ritter P. Echocardiographic modeling of cardiac dyssynchrony before and during multisite stimulation: a prospective study. Pacing Clin Electrophysiol. 2003:137-143. [pmid: 12687799].
Livanis EG, Flevari P, Theodorakis GN, Kolokathis F, Leftheriotis D, Kremastinos DT. Effect of biventricular pacing on heart rate variability in patients with chronic heart failure. Eur J Heart Fail. 2003:175-178. [pmid: 12644009].
Yu CM, Fung WH, Lin H, Zhang Q, Sanderson JE, Lau CP. Predictors of left ventricular reverse remodeling after cardiac resynchronization therapy for heart failure secondary to idiopathic dilated or ischemic cardiomyopathy. Am J Cardiol. 2003:684-688. [pmid: 12633798].
Mascioli G, Curnis A, Bontempi L, Dei Cas L. Biventricular pacing for patients with severe congestive heart failure: a single center experience. Ital Heart J. 2002:598-602. [pmid: 12478818].
Sogaard P, Egeblad H, Pedersen AK, Kim WY, Kristensen BO, Hansen PS, Mortensen PT. Sequential versus simultaneous biventricular resynchronization for severe heart failure: evaluation by tissue Doppler imaging. Circulation. 2002:2078-2084. [pmid: 12379577].
Ricci R, Pignalberi C, Ansalone G, Jannone E, Vaccaro MV, Denaro A, Cavaglia S, Santini M. Early and late QRS morphology and width in biventricular pacing: relationship to lead site and electrical remodeling. J Interv Card Electrophysiol. 2002:279-285. [pmid: 12154331].
Porciani MC, Sabini A, Colella A, Michelucci A, Musilli N, Pieragnoli P, Padeletti L. Interatrial septum pacing avoids the adverse effect of interatrial delay in biventricular pacing: an echo-Doppler evaluation. Europace. 2002:317-324. [pmid: 12134979].
Lamas GA, Lee KL, Sweeney MO, Silverman R, Leon A, Yee R, Marinchak RA, Flaker G, Schron E, Orav EJ, Hellkamp AS, Greer S, McAnulty J, Ellenbogen K, Ehlert F, Freedman RA, Estes NA 3rd, Greenspon A, Goldman L. Ventricular pacing or dual-chamber pacing for sinus-node dysfunction. N Engl J Med. 2002:1854-1862. [pmid: 12063369].
Ansalone G, Giannantoni P, Ricci R, Trambaiolo P, Fedele F, Santini M. Doppler myocardial imaging to evaluate the effectiveness of pacing sites in patients receiving biventricular pacing. J Am Coll Cardiol. 2002:489-499. [pmid: 11823088].
Butter C, Auricchio A, Stellbrink C, Fleck E, Ding J, Yu Y, Huvelle E, Spinelli J. Effect of resynchronization therapy stimulation site on the systolic function of heart failure patients. Circulation. 2001:3026-3029. [pmid: 11748094].
Ansalone G, Giannantoni P, Ricci R, Trambaiolo P, Laurenti A, Fedele F, Santini M. Doppler myocardial imaging in patients with heart failure receiving biventricular pacing treatment. Am Heart J. 2001:881-896. [pmid: 11685178].
Garrigue S, Jais P, Espil G, Labeque JN, Hocini M, Shah DC, Haissaguerre M, Clementy J. Comparison of chronic biventricular pacing between epicardial and endocardial left ventricular stimulation using Doppler tissue imaging in patients with heart failure. Am J Cardiol. 2001:858-862. [pmid: 11676947].
De Sutter J, De Bondt P, Van de Wiele C, Fonteyne W, Dierckx R, Clement D, Tavernier R. Prevalence of potential candidates for biventricular pacing among patients with known coronary artery disease: a prospective registry from a single center. Pacing Clin Electrophysiol. 2000:1718-1721. [pmid: 11139908].
Braunschweig F, Linde C, Gadler F, Ryden L. Reduction of hospital days by biventricular pacing. Eur J Heart Fail. 2000:399-406. [pmid: 11113717].
Stellbrink C, Auricchio A, Diem B, Breithardt OA, Kloss M, Schondube FA, Klein H, Messmer BJ, Hanrath P. Potential benefit of biventricular pacing in patients with congestive heart failure and ventricular tachyarrhythmia. Am J Cardiol. 99:143D-150D.
Saxon LA, Kerwin WF, Cahalan MK, Kalman JM, Olgin JE, Foster E, Schiller NB, Shinbane JS, Lesh MD, Merrick SH. Acute effects of intraoperative multisite ventricular pacing on left ventricular function and activation/contraction sequence in patients with depressed ventricular function. J Cardiovasc Electrophysiol. 98:13-21.
Auricchio A, Salo RW. Acute hemodynamic improvement by pacing in patients with severe congestive heart failure. Pacing Clin Electrophysiol. 97:313-324.
Cazeau S, Ritter P, Lazarus A, Gras D, Backdach H, Mundler O, Mugica J. Multisite pacing for end-stage heart failure: early experience. Pacing Clin Electrophysiol. 96:1748-1757.
Nishimura RA, Hayes DL, Holmes DR Jr, Tajik AJ. Mechanism of hemodynamic improvement by dual-chamber pacing for severe left ventricular dysfunction: an acute Doppler and catheterization hemodynamic study. J Am Coll Cardiol. 95:281-288.
Merchant FM, Kella D, Book WM, Langberg JJ, Lloyd MS. Cardiac resynchronization therapy in adult patients with repaired tetralogy of fallot and left ventricular systolic dysfunction. PACE Pacing Clin. Electrophysiol. 2014:321-328. [pmid: 24164147].
Arslan U, Balci MM, Kocaoglu I, Cimen T, Kalayci S, Temizhan A. The effects of cardiac resynchronization treatment on autonomic functions aside from functional status in heart failure: Kardiyak resenkronizasyon tedavisinin otonom sistem uzerine fonksiyonel kapasite otesinde etkileri. Anadolu Kardiyoloji Derg. 2013:439-445.
Ellims AH, Pfluger H, Elsik M, Butler MJ, Hare JL, Taylor AJ. Utility of cardiac magnetic resonance imaging, echocardiography and electrocardiography for the prediction of clinical response and long-term survival following cardiac resynchronisation therapy. Int. J. Card. Imaging. 2013:1303-1311.
Harris S, Tepper D, Ip R. Comparison of the Effects of Cardiac Resynchronization Therapy in Patients With Class II vs Class III and IV Heart Failure (From the InSync/InSync ICD Italian Registry). Congestive Heart Fail. 2013.
Lousinha A, Oliveira MM, Feliciano J, Galrinho A, Branco LM, Cunha PS, Hamad H, Ramos R, Abreu J, Leal A, Santos S, Soares R, Da Silva MN, Ferreira RC. Benefits of cardiac resynchronization therapy in &quot;Very dilated cardiomyopathy&quot;: Beneficios da terapeutica de ressincronizacao cardiaca na &lt;&lt;miocardiopatia muito dilatada&gt;&gt;. Rev. Port. Cardiol. 2011:283-294. [pmid: 21638987].
Holman WL, Kirklin JK, Naftel DC, Kormos RL, Desvign-Nickens P, Camacho MT, Ascheim DD. Infection after implantation of pulsatile mechanical circulatory support devices. J. Thorac. Cardiovasc. Surg. 2010:1632-1636.e2. [pmid: 20363482].
Ghanbari H, Feldman D, Schmidt M, Ottino J, MacHado C, Akoum N, Wall TS, Daccarett M. Cardiac resynchronization therapy device implantation in patients with therapeutic international normalized ratios. PACE Pacing Clin. Electrophysiol. 2010:400-406. [pmid: 20180915].
Takamatsu H, Tada H, Okaniwa H, Toide H, Maruyama H, Higuchi R, Kaseno K, Naito S, Kurabayashi M, Oshima S, Taniguchi K. Right bundle branch block and impaired left ventricular function as evidence of a left ventricular conduction delay. Circ. J. 2008:120-126. [pmid: 18159112].
Beshai JF, Truong Q. Resynchronization therapy in patients with narrow QRS (RethinQ). ACC Cardiosource Rev. J. 2008:44.
Landolina M, Lunati M, Gasparini M, Santini M, Padeletti L, Achilli A, Bianchi S, Laurenzi F, Curnis A, Vincenti A, Valsecchi S, Denaro A. Comparison of the Effects of Cardiac Resynchronization Therapy in Patients With Class II Versus Class III and IV Heart Failure (from the InSync/InSync ICD Italian Registry)(dagger)(dagger)Conflicts of interest: …. Am. J. Cardiol. 2007:1007-1012. [pmid: 17826388].
Phillips KP, Harberts DB, Johnston LP, O'Donnell D. Left ventricular resynchronization predicted by individual performance of right and left univentricular pacing: A study on the impact of sequential biventricular pacing on ventricular dyssynchrony. Heart Rhythm. 2007:147-153. [pmid: 17275748].
Cowburn PJ, Patel H, Jolliffe RE, Wald RW, Parker JD. Cardiac resynchronisation therapy: An option for inotrope-supported patients with end-stage heart failure?. Eur. J. Heart Fail. 2005:215-217. [pmid: 15701469].
Vogt J, Lamp B, Hansky B, Heintze J, Faber L, Guldner H, Korfer R, Horstkotte D. The Bad Oeynhausen experience. Eur. Heart. J. Suppl. 2004:D122-D127.
Liu X, Yu H, Pei J, Chu J, Pu J, Zhang S. Clinical Characteristics and Long-term Prognosis in Patients with Chronic Heart Failure and Reduced Ejection Fraction in China. Heart Lung Circul. 2014.
Al-Khatib SM, Hellkamp AS, Fonarow GC, Mark DB, Curtis LH, Hernandez AF, Anstrom KJ, Peterson ED, Sanders GD, Al-Khalidi HR, Hammill BG, Heidenreich PA, Hammill SC. Association between prophylactic implantable cardioverter-defibrillators and survival in patients with left ventricular ejection fraction between 30% and 35%. JAMA. 2014:2209-2215. [pmid: 24893088].
Facchini E, Varalda M, Sartori C, Burkhoff D, Marino PN. Systolic heart failure and cardiac resynchronization therapy: a focus on diastole. Int J Cardiovasc Imaging. 2014:897-905. [pmid: 24706254].
Varma N, Manne M, Nguyen D, He J, Niebauer M, Tchou P. Probability and magnitude of response to cardiac resynchronization therapy according to QRS duration and gender in nonischemic cardiomyopathy and LBBB. Heart Rhythm. 2014:1139-1147. [pmid: 24704570].
Padeletti L, Modesti PA, Cartei S, Checchi L, Ricciardi G, Pieragnolia P, Sacchi S, Padeletti M, Alterini B, Pantaleo P, Hu X, Tenori L, Luchinat C. Metabolomic does not predict response to cardiac resynchronization therapy in patients with heart failure. J Cardiovasc Med (Hagerstown). 2014:295-300. [pmid: 24699011].
Chan DD, Wu KC, Loring Z, Galeotti L, Gerstenblith G, Tomaselli G, Weiss RG, Wagner GS, Strauss DG. Comparison of the relation between left ventricular anatomy and QRS duration in patients with cardiomyopathy with versus without left bundle branch block. Am J Cardiol. 2014:1717-1722. [pmid: 24698465].
Reitan C, Bakos Z, Platonov PG, Hoijer CJ, Brandt J, Wang L, Borgquist R. Patient-assessed short-term positive response to cardiac resynchronization therapy is an independent predictor of long-term mortality. Europace. 2014.
Zanon F, Baracca E, Pastore G, Fraccaro C, Roncon L, Aggio S, Noventa F, Mazza A, Prinzen F. Determination of the longest intrapatient left ventricular electrical delay may predict acute hemodynamic improvement in patients after cardiac resynchronization therapy. Circ Arrhythm Electrophysiol. 2014:377-383. [pmid: 24668162].
Vegh EM, Kandala J, Orencole M, Upadhyay GA, Sharma A, Miller A, Merkely B, Parks KA, Singh JP. Device-measured physical activity versus six-minute walk test as a predictor of reverse remodeling and outcome after cardiac resynchronization therapy for heart failure. Am J Cardiol. 2014:1523-1528. [pmid: 24641966].
Killu AM, Grupper A, Friedman PA, Powell BD, Asirvatham SJ, Espinosa RE, Luria D, Rozen G, Buber J, Lee YH, Webster T, Brooke KL, Hodge DO, Wiste HJ, Glikson M, Cha YM. Predictors and outcomes of &quot;super-response&quot; to cardiac resynchronization therapy. J Card Fail. 2014:379-386. [pmid: 24632340].
Ge Y, Ruwald AC, Kutyifa V, McNitt S, Polonsky S, Klein H, Goldenberg I, Solomon SD, Foster E, Zareba W, Moss AJ. A metric for evaluating the cardiac response to resynchronization therapy. Am J Cardiol. 2014:1371-1377. [pmid: 24607029].
Plank B, Kutyifa V, Moss AJ, Huang DT, Ruwald AC, McNitt S, Polonsky B, Zareba W, Goldenberg I, Aktas MK. Smoking is associated with an increased risk of first and recurrent ventricular tachyarrhythmias in ischemic and nonischemic patients with mild heart failure: a MADIT-CRT substudy. Heart Rhythm. 2014:822-827. [pmid: 24509214].
Slyngstad T, Huth Ruwald AC, Kutyifa V, McNitt S, Polonsky B, Solomon SD, Foster E, Goldenberg I, Wang PJ, Klein H, Zareba W, Moss AJ. Cardiac resynchronization therapy is associated with reductions in left atrial volume and inappropriate implantable cardioverter-defibrillator therapy in MADIT-CRT. Heart Rhythm. 2014:1001-1007. [pmid: 24502968].
Rickard J, Cheng A, Spragg D, Green A, Leff B, Tang W, Cantillon D, Baranowski B, Wilkoff BL, Tchou P. Survival in octogenarians undergoing cardiac resynchronization therapy compared to the general population. Pacing Clin Electrophysiol. 2014:740-744. [pmid: 24471992].
Merlo M, Pivetta A, Pinamonti B, Stolfo D, Zecchin M, Barbati G, Di Lenarda A, Sinagra G. Long-term prognostic impact of therapeutic strategies in patients with idiopathic dilated cardiomyopathy: changing mortality over the last 30 years. Eur J Heart Fail. 2014:317-324. [pmid: 24464640].
Frigerio M, Lunati M, Pasqualucci D, Vargiu S, Foti G, Pedretti S, Vittori C, Cattafi G, Magenta G, Campo C, Bisetti S, Mercuro G. Left ventricular ejection fraction overcrossing 35% after one year of cardiac resynchronization therapy predicts long term survival and freedom from sudden cardiac death: single center observational experience. Int J Cardiol. 2014:64-71. [pmid: 24456869].
Aktas MK, Zareba W, Huang DT, McNitt S, Polonsky S, Chen L, Stockburger M, Merkely B, Moss AJ, Kutyifa V. The effect of weight loss on clinical outcomes in patients implanted with a cardiac resynchronization therapy device-A MADIT-CRT substudy. J Card Fail. 2014:183-189. [pmid: 24361804].
Mittal S, Shaw RE, Michel K, Palekar R, Arshad A, Musat D, Preminger M, Sichrovsky T, Steinberg JS. Cardiac implantable electronic device infections: incidence, risk factors, and the effect of the AigisRx antibacterial envelope. Heart Rhythm. 2014:595-601. [pmid: 24333543].
Ruwald AC, Pietrasik G, Goldenberg I, Kutyifa V, Daubert JP, Ruwald MH, Jons C, McNitt S, Wang P, Zareba W, Moss AJ. The effect of intermittent atrial tachyarrhythmia on heart failure or death in cardiac resynchronization therapy with defibrillator versus implantable cardioverter-defibrillator patients: a MADIT-CRT substudy (Multicenter Automatic Defibrillator Implantation Trial With Cardiac Resynchronization Therapy). J Am Coll Cardiol. 2014:1190-1197. [pmid: 24333490].
Chang PC, Wo HT, Chen TH, Wu D, Lin FC, Wang CC. Remote past left ventricular function before chronic right ventricular pacing predicts responses to cardiac resynchronization therapy upgrade. Pacing Clin Electrophysiol. 2014:454-463. [pmid: 24251726].
Gillis AM, Kerr CR, Philippon F, Newton G, Talajic M, Froeschl M, Froeschl S, Swiggum E, Yetisir E, Wells GA, Tang AS. Impact of cardiac resynchronization therapy on hospitalizations in the resynchronization-defibrillation for ambulatory heart failure trial. Circulation. 2014:2021-2030. [pmid: 24610807].
Skali H, Dwyer EM, Goldstein R, Haigney M, Krone R, Kukin M, Lichstein E, McNitt S, Moss AJ, Pfeffer MA, Solomon SD. Prognosis and response to therapy of first inpatient and outpatient heart failure event in a heart failure clinical trial: MADIT-CRT. European journal of heart failure. 2014:560-565. [pmid: 24578164].

## Address remodeling outcomes but response definition not within range of LVESV≥10%, LVEDV ≥10% or EF≥5%

Stockburger M, Nitardy A, Fateh-Moghadam S, Krebs A, Celebi O, Karhausen T, Dietz R. Electrical remodeling and cardiac dimensions in patients treated by cardiac resynchronization and heart failure controls. Pacing Clin Electrophysiol. 2008:70-77. [pmid: 18181912].
Stockburger M, Fateh-Moghadam S, Nitardy A, Celebi O, Krebs A, Habedank D, Dietz R. Baseline Doppler parameters are useful predictors of chronic left ventricular reduction in size by cardiac resynchronization therapy. Europace. 2008:69-74. [pmid: 18056135].
Becker M, Hoffmann R, Schmitz F, Hundemer A, Kuhl H, Schauerte P, Kelm M, Franke A. Relation of optimal lead positioning as defined by three-dimensional echocardiography to long-term benefit of cardiac resynchronization. Am J Cardiol. 2007:1671-1676. [pmid: 18036367].
Jansen AH, Peels KH, Bracke F, van Dantzig JM, Meijer A, van der Voort PH, van Gelder B, Korsten HH, van Hemel NM. Relation of isovolumic times after cardiac resynchronization therapy to improvement in exercise capacity. Am J Cardiol. 2007:75-78. [pmid: 17196466].
Pitzalis MV, Iacoviello M, Di Serio F, Romito R, Guida P, De Tommasi E, Luzzi G, Anaclerio M, Varraso L, Forleo C, Pansini N. Prognostic value of brain natriuretic peptide in the management of patients receiving cardiac resynchronization therapy. Eur J Heart Fail. 2006:509-514. [pmid: 16503416].
Macioce R, Cappelli F, Demarchi G, Lilli A, Ricciardi G, Pieragnoli P, Colella A, Michelucci A, Porciani MC, Padeletti L. Resynchronization of mitral valve annular segments reduces functional mitral regurgitation in cardiac resynchronization therapy. Minerva Cardioangiol. 2005:329-333. [pmid: 16177677].
Bonanno C, Ometto R, Pasinato S, Finocchi G, La Vecchia L, Fontanelli A. Effects of cardiac resynchronization therapy on disease progression in patients with congestive heart failure. Ital Heart J. 2004:364-370. [pmid: 15185900].
De Roest G, Knaapen P, Gotte M, Hendriks T, Allaart C, De Cock C, Van Rossum A. Stroke work or systolic dP/dtmax to evaluate acute response to cardiac resynchronization therapy: are they interchangeable?. Eur. J. Heart Fail. 2009:706-708. [pmid: 19553399].

## Study addresses predictor questions but does not adjust via model or participant selection for at least 2 predictor of Gender, QRS Duration and/or Morphology

Ogano M, Iwasaki YK, Tanabe J, Takagi H, Umemoto T, Hayashi M, Miyauchi Y, Shimizu W. Cardiac resynchronization therapy restored ventricular septal myocardial perfusion and enhanced ventricular remodeling in patients with nonischemic cardiomyopathy presenting with left bundle branch block. Heart Rhythm. 2014.
Chang PC, Wo HT, Chen TH, Wu D, Lin FC, Wang CC. Remote Past Left Ventricular Function before Chronic Right Ventricular Pacing Predicts Responses to Cardiac Resynchronization Therapy Upgrade. Pacing Clin Electrophysiol. 2013.
Dong YX, Oh JK, Yang YZ, Cha YM. Left ventricular 12 segmental strain imaging predicts response to cardiac resynchronization therapy. Chin Med J (Engl). 2013:2620-2624. [pmid: 23876883].
Rossi L, Malagoli A, Piepoli M, Franchi F, Malavasi V, Casali E, Rusticali G, Villani GQ. Indexed maximal left atrial volume predicts response to cardiac resynchronization therapy. Int J Cardiol. 2013:3629-3633. [pmid: 23725913].
Sade LE, Ozin B, Atar I, Demir O, Demirtas S, Muderrisoglu H. Right ventricular function is a determinant of long-term survival after cardiac resynchronization therapy. J Am Soc Echocardiogr. 2013:706-713. [pmid: 23611060].
Minamiguchi H, Sakata Y, Ohtani T, Mizote I, Takeda Y, Mizuno H, Okuyama Y, Nakatani S, Fujita M, Watanabe T, Uematsu M, Komuro I. Usefulness of overlapping of the E and A waves of the transmitral flow as a predictor of responders to cardiac resynchronization therapy. Am J Cardiol. 2013:1613-1618. [pmid: 23497774].
Knappe D, Pouleur AC, Shah AM, Bourgoun M, Brown MW, Foster E, Pfeffer MA, Moss AJ, Solomon SD. Acute effects of withdrawal of cardiac resynchronization therapy on left and right ventricular function, dyssynchrony, and contractile function in patients with New York Heart Association functional class I/II heart failure: MADIT-CRT. J Card Fail. 2013:149-155. [pmid: 23482074].
Cochet H, Denis A, Ploux S, Lumens J, Amraoui S, Derval N, Sacher F, Reant P, Lafitte S, Jais P, Laurent F, Ritter P, Montaudon M, Bordachar P. Pre- and intra-procedural predictors of reverse remodeling after cardiac resynchronization therapy: an MRI study. J Cardiovasc Electrophysiol. 2013:682-691. [pmid: 23437804].
Kydd AC, Khan FZ, O'Halloran D, Pugh PJ, Virdee MS, Dutka DP. Radial strain delay based on segmental timing and strain amplitude predicts left ventricular reverse remodeling and survival after cardiac resynchronization therapy. Circ Cardiovasc Imaging. 2013:177-184. [pmid: 23363579].
Bertini M, Hoke U, van Bommel RJ, Ng AC, Shanks M, Nucifora G, Auger D, Borleffs CJ, van Rijnsoever EP, van Erven L, Schalij MJ, Marsan NA, Bax JJ, Delgado V. Impact of clinical and echocardiographic response to cardiac resynchronization therapy on long-term survival. Eur Heart J Cardiovasc Imaging. 2013:774-781. [pmid: 23221312].
Shanks M, Antoni ML, Hoke U, Bertini M, Ng AC, Auger D, Marsan NA, van Erven L, Holman ER, Schalij MJ, Bax JJ, Delgado V. The effect of cardiac resynchronization therapy on left ventricular diastolic function assessed with speckle-tracking echocardiography. Eur J Heart Fail. 2011:1133-1139. [pmid: 21873339].
Martin DT, McNitt S, Nesto RW, Rutter MK, Moss AJ. Cardiac resynchronization therapy reduces the risk of cardiac events in patients with diabetes enrolled in the multicenter automatic defibrillator implantation trial with cardiac resynchronization therapy (MADIT-CRT). Circ Heart Fail. 2011:332-338. [pmid: 21350054].
Smit MD, Maass AH, Hillege HL, Wiesfeld AC, Van Veldhuisen DJ, Van Gelder IC. Prognostic importance of natriuretic peptides and atrial fibrillation in patients receiving cardiac resynchronization therapy. Eur J Heart Fail. 2011:543-550. [pmid: 21330294].
Zaca V, Baiocchi C, Gaddi R, Gentilini R, Lunghetti S, Padeletti M, Pagliaro A, Furiozzi F, Mondillo S, Favilli R. Influence of aetiology on long-term effects of resynchronization on cardiac structure and function in patients treated with beta-blockers. J Cardiovasc Med (Hagerstown). 2011:227-233. [pmid: 21252694].
McLeod CJ, Shen WK, Rea RF, Friedman PA, Hayes DL, Wokhlu A, Webster TL, Wiste HJ, Hodge DO, Bradley DJ, Hammill SC, Packer DL, Cha YM. Differential outcome of cardiac resynchronization therapy in ischemic cardiomyopathy and idiopathic dilated cardiomyopathy. Heart Rhythm. 2011:377-382. [pmid: 21070886].
van Bommel RJ, van Rijnsoever E, Borleffs CJ, Delgado V, Marsan NA, Bertini M, Schalij MJ, Bax JJ. Effect of cardiac resynchronization therapy in patients with New York Heart Association functional class IV heart failure. Am J Cardiol. 2010:1146-1151. [pmid: 20920655].
Muto C, Gasparini M, Neja CP, Iacopino S, Davinelli M, Zanon F, Dicandia C, Distefano G, Donati R, Calvi V, Denaro A, Tuccillo B. Presence of left ventricular contractile reserve predicts midterm response to cardiac resynchronization therapy--results from the LOw dose DObutamine stress-echo test in Cardiac Resynchronization Therapy (LODO-CRT) trial. Heart Rhythm. 2010:1600-1605. [pmid: 20691283].
Chandra R, Zolty R, Palma E. A left hemiblock improves cardiac resynchronization therapy outcomes in patients with a right bundle branch block. Clin Cardiol. 2010:89-93. [pmid: 20186989].
Galrinho A, Branco LM, Oliveira MM, Da Silva N, Abreu J, Santos S, Leal A, Ferreira RC. Cardiac resynchronization therapy--clinical and echocardiographic characteristics of responders and exceptional responders. Rev Port Cardiol. 2009:959-969. [pmid: 19998807].
Sassone B, Gabrieli L, Sacca S, Boggian G, Fusco A, Pratola C, Bacchi-Reggiani ML, Padeletti L, Barold SS. Value of right ventricular-left ventricular interlead electrical delay to predict reverse remodelling in cardiac resynchronization therapy: the INTER-V pilot study. Europace. 2010:78-83. [pmid: 19897503].
Nazeri A, Massumi A, Rasekh A, Saeed M, Frank C, Razavi M. Cardiac resynchronization therapy in patients with right ventricular pacing-induced cardiomyopathy. Pacing Clin Electrophysiol. 2010:37-40. [pmid: 19821931].
Bonakdar HR, Jorat MV, Fazelifar AF, Alizadeh A, Givtaj N, Sameie N, Sadeghpour A, Haghjoo M. Prediction of response to cardiac resynchronization therapy using simple electrocardiographic and echocardiographic tools. Europace. 2009:1330-1337. [pmid: 19797149].
van Bommel RJ, Bax JJ, Abraham WT, Chung ES, Pires LA, Tavazzi L, Zimetbaum PJ, Gerritse B, Kristiansen N, Ghio S. Characteristics of heart failure patients associated with good and poor response to cardiac resynchronization therapy: a PROSPECT (Predictors of Response to CRT) sub-analysis. Eur Heart J. 2009:2470-2477. [pmid: 19717847].
Wilinski J, Czarnecka D, Wojciechowska W, Kloch-Badelek M, Jastrzebski M, Bacior B, Kwiecien-Sobstel A, Kawecka-Jaszcz K. Different response rates to cardiac resynchronization therapy (CRT) according to the applied definition. Przegl Lek. 2009:130-133. [pmid: 19689037].
Kleijn SA, van Dijk J, de Cock CC, Allaart CP, van Rossum AC, Kamp O. Assessment of intraventricular mechanical dyssynchrony and prediction of response to cardiac resynchronization therapy: comparison between tissue Doppler imaging and real-time three-dimensional echocardiography. J Am Soc Echocardiogr. 2009:1047-1054. [pmid: 19647409].
Shi H, Shu X, Wang F, Cui J, Chen H, Sun B, Liu S. Longitudinal two-dimensional strain rate imaging: a potential approach to predict the response to cardiac resynchronization therapy. Int J Cardiovasc Imaging. 2009:677-687. [pmid: 19639392].
Leyva F, Foley PW, Stegemann B, Ward JA, Ng LL, Frenneaux MP, Regoli F, Smith RE, Auricchio A. Development and validation of a clinical index to predict survival after cardiac resynchronisation therapy. Heart. 2009:1619-1625. [pmid: 19592389].
Ding L, Hua W, Zhang S, Chu J, Chen K, Wang F, Chen X. Improvement of P wave dispersion after cardiac resynchronization therapy for heart failure. J Electrocardiol. 2009:334-338. [pmid: 19539810].
Delgado V, Ypenburg C, Zhang Q, Mollema SA, Fung JW, Schalij MJ, Yu CM, Bax JJ. Changes in global left ventricular function by multidirectional strain assessment in heart failure patients undergoing cardiac resynchronization therapy. J Am Soc Echocardiogr. 2009:688-694. [pmid: 19501328].
Soliman OI, Geleijnse ML, Theuns DA, van Dalen BM, Vletter WB, Jordaens LJ, Metawei AK, Al-Amin AM, ten Cate FJ. Usefulness of left ventricular systolic dyssynchrony by real-time three-dimensional echocardiography to predict long-term response to cardiac resynchronization therapy. Am J Cardiol. 2009:1586-1591. [pmid: 19463520].
Foley PW, Muhyaldeen SA, Chalil S, Smith RE, Sanderson JE, Leyva F. Long-term effects of upgrading from right ventricular pacing to cardiac resynchronization therapy in patients with heart failure. Europace. 2009:495-501. [pmid: 19307283].
Castellant P, Fatemi M, Orhan E, Etienne Y, Blanc JJ. Patients with non-ischaemic dilated cardiomyopathy and hyper-responders to cardiac resynchronization therapy: characteristics and long-term evolution. Europace. 2009:350-355. [pmid: 19240110].
Maass AH, Buck S, Nieuwland W, Brugemann J, van Veldhuisen DJ, Van Gelder IC. Importance of heart rate during exercise for response to cardiac resynchronization therapy. J Cardiovasc Electrophysiol. 2009:773-780. [pmid: 19207785].
Markowitz SM, Lewen JM, Wiggenhorn CJ, Abraham WT, Stein KM, Iwai S, Lerman BB. Relationship of reverse anatomical remodeling and ventricular arrhythmias after cardiac resynchronization. J Cardiovasc Electrophysiol. 2009:293-298. [pmid: 19175852].
Alper AT, Akyol A, Hasdemir H, Yildirim A, Nurkalem Z, Guvenc TS, Cakmak N, Oguz E, Erdinler IC, Gurkan K. Effect of cardiac resynchronization therapy on mean platelet volume. Acta Cardiol. 2008:735-739. [pmid: 19157169].
Brandao SC, Nishioka SA, Giorgi MC, Chen J, Abe R, Martinelli Filho M, Hotta VT, Vieira ML, Garcia EV, Meneghetti JC. Cardiac resynchronization therapy evaluated by myocardial scintigraphy with 99mTc-MIBI: changes in left ventricular uptake, dyssynchrony, and function. Eur J Nucl Med Mol Imaging. 2009:986-996. [pmid: 19145431].
Castel MA, Mendez F, Tamborero D, Mont L, Magnani S, Tolosana JM, Berruezo A, Godoy M, Sitges M, Vidal B, Roig E, Brugada J. Six-minute walking test predicts long-term cardiac death in patients who received cardiac resynchronization therapy. Europace. 2009:338-342. [pmid: 19136491].
Lafitte S, Reant P, Zaroui A, Donal E, Mignot A, Bougted H, Belghiti H, Bordachar P, Deplagne A, Chabaneix J, Franceschi F, Deharo JC, Dos Santos P, Clementy J, Roudaut R, Leclercq C, Habib G. Validation of an echocardiographic multiparametric strategy to increase responders patients after cardiac resynchronization: a multicentre study. Eur Heart J. 2009:2880-2887. [pmid: 19136487].
Tanaka Y, Tada H, Yamashita E, Sato C, Irie T, Hori Y, Goto K, Iwamoto J, Manni H, Yokokawa M, Naito S, Oshima S, Taniguchi K. Change in blood pressure just after initiation of cardiac resynchronization therapy predicts long-term clinical outcome in patients with advanced heart failure. Circ J. 2009:288-294. [pmid: 19110507].
Kelarijani RB, Saleh DK, Chalian M, Kabir A, Ahmadzad Asl M, Dadjoo Y. Gender- and age-related outcomes of cardiac resynchronization therapy: a pilot observational study. Gend Med. 2008:415-422. [pmid: 19108814].
Wiesbauer F, Baytaroglu C, Azar D, Blessberger H, Goliasch G, Graf S, Mundigler G, Pacher R, Maurer G, Binder T. Echo Doppler parameters predict response to cardiac resynchronization therapy. Eur J Clin Invest. 2009:1-10. [pmid: 19087125].
Garcia-Seara J, Martinez-Sande JL, Cid B, Gude F, Bastos M, Dominguez M, Varela A, Gonzalez-Juanatey JR. Influence of the preimplantation QRS axis on responses to cardiac resynchronization therapy. Rev Esp Cardiol. 2008:1245-1252. [pmid: 19080962].
Gasparini M, Lunati M, Landolina M, Santini M, Padeletti L, Perego G, Vincenti A, Curnis A, Carboni A, Denaro A, Spotti A, Grammatico A, Regoli F, Boriani G. Electrical storm in patients with biventricular implantable cardioverter defibrillator: incidence, predictors, and prognostic implications. Am Heart J. 2008:847-854. [pmid: 19061697].
Fung JW, Lam YY, Zhang Q, Yip GW, Chan WW, Chan GC, Chan JY, Yu CM. Effect of left ventricular lead concordance to the delayed contraction segment on echocardiographic and clinical outcomes after cardiac resynchronization therapy. J Cardiovasc Electrophysiol. 2009:530-535. [pmid: 19054250].
Sredniawa B, Lenarczyk R, Kowalski O, Pruszkowska-Skrzep P, Kowalczyk J, Musialik-Lydka A, Cebula S, Kalarus Z. Sleep apnoea as a predictor of mid- and long-term outcome in patients undergoing cardiac resynchronization therapy. Europace. 2009:106-114. [pmid: 19008239].
Parsai C, Bijnens B, Sutherland GR, Baltabaeva A, Claus P, Marciniak M, Paul V, Scheffer M, Donal E, Derumeaux G, Anderson L. Toward understanding response to cardiac resynchronization therapy: left ventricular dyssynchrony is only one of multiple mechanisms. Eur Heart J. 2009:940-949. [pmid: 19004844].
Rocchi G, Bertini M, Biffi M, Ziacchi M, Biagini E, Gallelli I, Martignani C, Cervi E, Ferlito M, Rapezzi C, Branzi A, Boriani G. Exercise stress echocardiography is superior to rest echocardiography in predicting left ventricular reverse remodelling and functional improvement after cardiac resynchronization therapy. Eur Heart J. 2009:89-97. [pmid: 18987095].
Hoth KF, Nash J, Poppas A, Ellison KE, Paul RH, Cohen RA. Effects of cardiac resynchronization therapy on health-related quality of life in older adults with heart failure. Clin Interv Aging. 2008:553-560. [pmid: 18982925].
Lepillier A, Piot O, Gerritse B, Copie X, Lavergne T, Paziaud O, Lascault G, Waintraub X, Otmani A, Le Heuzey JY. Relationship between New York Heart Association class change and ventricular tachyarrhythmia occurrence in patients treated with cardiac resynchronization plus defibrillator. Europace. 2009:80-85. [pmid: 18952828].
Mangiavacchi M, Gasparini M, Genovese S, Pini D, Klersy C, Bragato R, Andreuzzi B, Municino A, Regoli F, Galimberti P, Ceriotti C, Gronda E. Insulin-treated type 2 diabetes is associated with a decreased survival in heart failure patients after cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2008:1425-1432. [pmid: 18950300].
Kimura S, Ito M, Chinushi M, Tanaka K, Tanabe Y, Hosaka Y, Komura S, Okada S, Iijima K, Furushima H, Fuse K, Sato M, Aizawa Y. Preservation of renal function in response to cardiac resynchronization therapy. Circ J. 2008:1794-1799. [pmid: 18838826].
Landolina M, Gasparini M, Lunati M, Santini M, Rordorf R, Vincenti A, Diotallevi P, Montenero AS, Bonanno C, De Santo T, Valsecchi S, Padeletti L. Heart rate variability monitored by the implanted device predicts response to CRT and long-term clinical outcome in patients with advanced heart failure. Eur J Heart Fail. 2008:1073-1079. [pmid: 18838333].
Nagele H, Dodeck J, Behrens S, Azizi M, Hashagen S, Eisermann C, Castel MA. Hemodynamics and prognosis after primary cardiac resynchronization system implantation compared to &quot;upgrade&quot; procedures. Pacing Clin Electrophysiol. 2008:1265-1271. [pmid: 18811806].
Hina K, Kawamura H, Murakami T, Yamamoto K, Yamaji H, Murakami M, Hirohata S, Ogawa H, Sakane K, Kusachi S. Association of corrected QT dispersion with symptoms improvement in patients receiving cardiac resynchronization therapy. Heart Vessels. 2008:325-333. [pmid: 18810581].
Riedlbauchova L, Brunken R, Jaber WA, Popova L, Patel D, Lanska V, Civello K, Cummings J, Burkhardt JD, Saliba W, Martin D, Schweikert R, Wilkoff BL, Grimm R, Natale A. The impact of myocardial viability on the clinical outcome of cardiac resynchronization therapy. J Cardiovasc Electrophysiol. 2009:50-57. [pmid: 18803571].
Marsan NA, Bleeker GB, Ypenburg C, Van Bommel RJ, Ghio S, Van de Veire NR, Delgado V, Holman ER, van der Wall EE, Schalij MJ, Bax JJ. Real-time three-dimensional echocardiography as a novel approach to assess left ventricular and left atrium reverse remodeling and to predict response to cardiac resynchronization therapy. Heart Rhythm. 2008:1257-1264. [pmid: 18774099].
Umar S, Bax JJ, Klok M, van Bommel RJ, Hessel MH, den Adel B, Bleeker GB, Henneman MM, Atsma DE, van der Wall EE, Schalij MJ, van der Laarse A. Myocardial collagen metabolism in failing hearts before and during cardiac resynchronization therapy. Eur J Heart Fail. 2008:878-883. [pmid: 18768351].
Di Biase L, Auricchio A, Sorgente A, Civello K, Klersy C, Faletra F, Riedlbauchova L, Patel D, Arruda M, Schweikert RA, Martin DO, Saliba WI, Moccetti T, Wilkoff BL, Natale A. The magnitude of reverse remodelling irrespective of aetiology predicts outcome of heart failure patients treated with cardiac resynchronization therapy. Eur Heart J. 2008:2497-2505. [pmid: 18515806].
Kirn B, Jansen A, Bracke F, van Gelder B, Arts T, Prinzen FW. Mechanical discoordination rather than dyssynchrony predicts reverse remodeling upon cardiac resynchronization. Am J Physiol Heart Circ Physiol. 2008:H640-H646. [pmid: 18515652].
Ferreira AM, Adragao P, Cavaco DM, Candeias R, Morgado FB, Santos KR, Santos E, Silva JA. Benefit of cardiac resynchronization therapy in atrial fibrillation patients vs. patients in sinus rhythm: the role of atrioventricular junction ablation. Europace. 2008:809-815. [pmid: 18511438].
Chwyczko T, Sterlinski M, Maciag A, Firek B, Labecka A, Jankowska A, Kosmicki M, Kowalik I, Malczewska B, Szwed H. Impact of cardiac resynchronisation therapy on adaptation of circulatory and respiratory systems to exercise assessed by cardiopulmonary exercise test in patients with chronic heart failure. Kardiol Pol. 2008:406-412. discussion 413-4. [pmid: 18473269].
Kelarijani RB, Dadjoo Y, Chalian H, Naserbakht M, Kabir K, Saleh DK. Over-time mitral regurgitation changes following cardiac resynchronization therapy. Adv Med Sci. 2008:94-98. [pmid: 18467272].
Chung ES, Leon AR, Tavazzi L, Sun JP, Nihoyannopoulos P, Merlino J, Abraham WT, Ghio S, Leclercq C, Bax JJ, Yu CM, Gorcsan J 3rd, St John Sutton M, De Sutter J, Murillo J. Results of the Predictors of Response to CRT (PROSPECT) trial. Circulation. 2008:2608-2616. [pmid: 18458170].
Shalaby A, El-Saed A, Voigt A, Albany C, Saba S. Elevated serum creatinine at baseline predicts poor outcome in patients receiving cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2008:575-579. [pmid: 18439171].
Rogers DP, Marazia S, Chow AW, Lambiase PD, Lowe MD, Frenneaux M, McKenna WJ, Elliott PM. Effect of biventricular pacing on symptoms and cardiac remodelling in patients with end-stage hypertrophic cardiomyopathy. Eur J Heart Fail. 2008:507-513. [pmid: 18406204].
Oginosawa Y, Nogami A, Soejima K, Aonuma K, Kubota S, Sato T, Sugiyasu A, Yoshida K, Kowase S, Sakamaki M, Kurosaki K, Kato K. Effect of cardiac resynchronization therapy in isolated ventricular noncompaction in adults: follow-up of four cases. J Cardiovasc Electrophysiol. 2008:935-938. [pmid: 18399967].
Delnoy PP, Ottervanger JP, Luttikhuis HO, Elvan A, Misier AR, Beukema WP, van Hemel NM. Clinical response of cardiac resynchronization therapy in the elderly. Am Heart J. 2008:746-751. [pmid: 18371486].
Nayak HM, Verdino RJ, Russo AM, Gerstenfeld EP, Hsia HH, Lin D, Dixit S, Cooper JM, Callans DJ, Marchlinski FE. Ventricular tachycardia storm after initiation of biventricular pacing: incidence, clinical characteristics, management, and outcome. J Cardiovasc Electrophysiol. 2008:708-715. [pmid: 18363690].
Burri H, Sunthorn H, Somsen A, Fleury E, Stettler C, Shah D, Righetti A. Improvement in cardiac sympathetic nerve activity in responders to resynchronization therapy. Europace. 2008:374-378. [pmid: 18308757].
Soliman OI, Geleijnse ML, Theuns DA, Nemes A, Vletter WB, van Dalen BM, Motawea AK, Jordaens LJ, ten Cate FJ. Reverse of left ventricular volumetric and structural remodeling in heart failure patients treated with cardiac resynchronization therapy. Am J Cardiol. 2008:651-657. [pmid: 18308015].
Novak M, Lipoldova J, Kamaryt P, Dvorak J Jr, Ozabalova E, Vank P, Hude P, Krejci J. Cardiac resynchronization therapy. Midterm follow-up of 128 patients. Bratisl Lek Listy. 2007:445-452. [pmid: 18306724].
Faran A, Lewicka-Nowak E, Dabrowska-Kugacka A, Kempa M, Tybura S, Szwoch M, Krolak T, Raczak G. Cardiac resynchronisation therapy in patients with end-stage heart failure--long-term follow-up. Kardiol Pol. 2008:19-26. discussion 27. [pmid: 18266184].
Castellant P, Fatemi M, Bertault-Valls V, Etienne Y, Blanc JJ. Cardiac resynchronization therapy: &quot;nonresponders&quot; and &quot;hyperresponders&quot;. Heart Rhythm. 2008:193-197. [pmid: 18242538].
Khadjooi K, Foley PW, Chalil S, Anthony J, Smith RE, Frenneaux MP, Leyva F. Long-term effects of cardiac resynchronisation therapy in patients with atrial fibrillation. Heart. 2008:879-883. [pmid: 18208826].
Zhang Q, Fung JW, Yip GW, Chan JY, Lee AP, Lam YY, Wu LW, Wu EB, Yu CM. Improvement of left ventricular myocardial short-axis, but not long-axis function or torsion after cardiac resynchronisation therapy: an assessment by two-dimensional speckle tracking. Heart. 2008:1464-1471. [pmid: 18198202].
Vanderheyden M, Mullens W, Delrue L, Goethals M, de Bruyne B, Wijns W, Geelen P, Verstreken S, Wellens F, Bartunek J. Myocardial gene expression in heart failure patients treated with cardiac resynchronization therapy responders versus nonresponders. J Am Coll Cardiol. 2008:129-136. [pmid: 18191736].
Wojcicka M, Sterlinski M, Chwyczko T, Smolis-Bak E, Szwed H, Kowalik I. Quality of life in patients undergoing cardiac resynchronisation therapy. Kardiol Pol. 2007:1425-1430. discussion 1431-2. [pmid: 18181054].
Sterlinski M, Maciag A, Kowalski O, Goscinska-Bis K, Pytkowski M, Kowalik I, Lewicka-Nowak E, Mitkowski P, Kazmierczak J, Kalarus Z, Kargul W, Lubinski A, Cieslinski A, Kornacewicz-Jach Z, Szwed H, Sadowski Z. Mortality in patients with heart failure treated with cardiac resynchronisation therapy. A long-term multi-centre follow-up study. Kardiol Pol. 2007:1287-1293. discussion 1294-5. [pmid: 18058579].
Mollema SA, Bleeker GB, van der Wall EE, Schalij MJ, Bax JJ. Usefulness of QRS duration to predict response to cardiac resynchronization therapy in patients with end-stage heart failure. Am J Cardiol. 2007:1665-1670. [pmid: 18036366].
Nishioka SA, Martinelli Filho M, Brandao SC, Giorgi MC, Vieira ML, Costa R, Mathias W, Meneghetti JC. Cardiac sympathetic activity pre and post resynchronization therapy evaluated by 123I-MIBG myocardial scintigraphy. J Nucl Cardiol. 2007:852-859. [pmid: 18022112].
Gradaus R, Stuckenborg V, Loher A, Kobe J, Reinke F, Gunia S, Vahlhaus C, Breithardt G, Bruch C. Diastolic filling pattern and left ventricular diameter predict response and prognosis after cardiac resynchronisation therapy. Heart. 2008:1026-1031. [pmid: 17984216].
Lellouche N, De Diego C, Vaseghi M, Buch E, Cesario DA, Mahajan A, Wiener I, Fonarow GC, Boyle NG, Shivkumar K. Cardiac resynchronization therapy response is associated with shorter duration of atrial fibrillation. Pacing Clin Electrophysiol. 2007:1363-1368. [pmid: 17976100].
Zardkoohi O, Nandigam V, Murray L, Heist EK, Mela T, Orencole M, Ruskin JN, Singh JP. The impact of age and gender on cardiac resynchronization therapy outcome. Pacing Clin Electrophysiol. 2007:1344-1348. [pmid: 17976097].
Yannopoulos D, Lurie KG, Sakaguchi S, Milstein S, Ermis C, VanHeel L, Benditt DG. Reduced atrial tachyarrhythmia susceptibility after upgrade of conventional implanted pulse generator to cardiac resynchronization therapy in patients with heart failure. J Am Coll Cardiol. 2007:1246-1251. [pmid: 17888841].
Landolina M, Lunati M, Gasparini M, Santini M, Padeletti L, Achilli A, Bianchi S, Laurenzi F, Curnis A, Vincenti A, Valsecchi S, Denaro A. Comparison of the effects of cardiac resynchronization therapy in patients with class II versus class III and IV heart failure (from the InSync/InSync ICD Italian Registry). Am J Cardiol. 2007:1007-1012. [pmid: 17826388].
Sunsaneewitayakul B, Sitthisook S, Sangwatanaroj S, Prechawat S, Songmuang SB. Feasibility, safety, and mid-term efficacy of cardiac resynchronization therapy in patients with severe heart failure and ventricular conduction delay: Chulalongkorn experience. J Med Assoc Thai. 2007:1458-1466. [pmid: 17710992].
Yu CM, Fang F, Zhang Q, Yip GW, Li CM, Chan JY, Wu L, Fung JW. Improvement of atrial function and atrial reverse remodeling after cardiac resynchronization therapy for heart failure. J Am Coll Cardiol. 2007:778-785. [pmid: 17707183].
Res JC, Bokern MJ, de Cock CC, van Loenhout T, Bronzwaer PN, Spierenburg HA. The BRIGHT study: bifocal right ventricular resynchronization therapy: a randomized study. Europace. 2007:857-861. [pmid: 17684064].
Gimelli A, Stanislao M, Valle G, Frumento P, Zanco P, Ometto R, Inglese E, Martino G, Startari U, Bertelli P, Marzullo P. Volume overload modulates effects of cardiac resynchronization therapy independently of myocardial reperfusion: results of the RESYNC study. J Cardiovasc Med (Hagerstown). 2007:575-581. [pmid: 17667027].
Samesima N, Douglas R, Tobias N, Pedrosa A, Martinelli Filho M, Ramires JA, Pastore CA. Twenty-millisecond interventricular difference as assessed by body surface potential mapping identifies patients with clinical improvement after implantation of cardiac resynchronization device. Anadolu Kardiyol Derg. 2007:213-215. [pmid: 17584728].
Sassone B, Capecchi A, Boggian G, Gabrieli L, Sacca S, Vandelli R, Petracci E, Mele D. Value of baseline left lateral wall postsystolic displacement assessed by M-mode to predict reverse remodeling by cardiac resynchronization therapy. Am J Cardiol. 2007:470-475. [pmid: 17659931].
Herweg B, Ilercil A, Cutro R, Dewhurst R, Krishnan S, Weston M, Barold SS. Cardiac resynchronization therapy in patients with end-stage inotrope-dependent class IV heart failure. Am J Cardiol. 2007:90-93. [pmid: 17599447].
Seifert M, Schlegl M, Hoersch W, Fleck E, Doelger A, Stockburger M, Butter C. Functional capacity and changes in the neurohormonal and cytokine status after long-term CRT in heart failure patients. Int J Cardiol. 2007:68-73. [pmid: 17582527].
Henneman MM, Chen J, Dibbets-Schneider P, Stokkel MP, Bleeker GB, Ypenburg C, van der Wall EE, Schalij MJ, Garcia EV, Bax JJ. Can LV dyssynchrony as assessed with phase analysis on gated myocardial perfusion SPECT predict response to CRT?. J Nucl Med. 2007:1104-1111. [pmid: 17574987].
Cabrera-Bueno F, Garcia-Pinilla JM, Pena-Hernandez J, Jimenez-Navarro M, Gomez-Doblas JJ, Barrera-Cordero A, Alzueta-Rodriguez J, de Teresa-Galvan E. Repercussion of functional mitral regurgitation on reverse remodelling in cardiac resynchronization therapy. Europace. 2007:757-761. [pmid: 17573358].
Yuan XP, White JA, Yee R, Drangova M. Tissue Doppler imaging of mitral annular motion is an effective surrogate of left ventricular dyssynchrony and predicts response to cardiac resynchronization therapy. J Am Soc Echocardiogr. 2007:1186-1193. [pmid: 17570638].
Shimano M, Tsuji Y, Yoshida Y, Inden Y, Tsuboi N, Itoh T, Suzuki H, Muramatsu T, Okada T, Harata S, Yamada T, Hirayama H, Nattel S, Murohara T. Acute and chronic effects of cardiac resynchronization in patients developing heart failure with long-term pacemaker therapy for acquired complete atrioventricular block. Europace. 2007:869-874. [pmid: 17557768].
Richardson M, Freemantle N, Calvert MJ, Cleland JG, Tavazzi L. Predictors and treatment response with cardiac resynchronization therapy in patients with heart failure characterized by dyssynchrony: a pre-defined analysis from the CARE-HF trial. Eur Heart J. 2007:1827-1834. [pmid: 17540848].
Iyengar S, Haas G, Lamba S, Orsinelli DA, Babu GJ, Ferketich AK, Yamokoski L, Periasamy M, Abraham WT. Effect of cardiac resynchronization therapy on myocardial gene expression in patients with nonischemic dilated cardiomyopathy. J Card Fail. 2007:304-311. [pmid: 17517351].
Madaric J, Vanderheyden M, Van Laethem C, Verhamme K, Feys A, Goethals M, Verstreken S, Geelen P, Penicka M, De Bruyne B, Bartunek J. Early and late effects of cardiac resynchronization therapy on exercise-induced mitral regurgitation: relationship with left ventricular dyssynchrony, remodelling and cardiopulmonary performance. Eur Heart J. 2007:2134-2141. [pmid: 17504802].
Lane RE, Mayet J, Peters NS, Davies DW, Chow AW. Comparison of temporary bifocal right ventricular pacing and biventricular pacing for heart failure: evaluation by tissue Doppler imaging. Heart. 2008:53-58. [pmid: 17483133].
Delnoy PP, Ottervanger JP, Luttikhuis HO, Elvan A, Misier AR, Beukema WP, van Hemel NM. Comparison of usefulness of cardiac resynchronization therapy in patients with atrial fibrillation and heart failure versus patients with sinus rhythm and heart failure. Am J Cardiol. 2007:1252-1257. [pmid: 17478153].
Oldenburg O, Faber L, Vogt J, Dorszewski A, Szabados F, Horstkotte D, Lamp B. Influence of cardiac resynchronisation therapy on different types of sleep disordered breathing. Eur J Heart Fail. 2007:820-826. [pmid: 17467333].
Stern J, Heist EK, Murray L, Alabiad C, Chung J, Picard MH, Semigran MJ, Ruskin JN, Singh JP. Elevated estimated pulmonary artery systolic pressure is associated with an adverse clinical outcome in patients receiving cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2007:603-607. [pmid: 17461868].
Michelucci A, Ricciardi G, Sofi F, Gori AM, Pirolo F, Pieragnoli P, Giaccardi M, Colella A, Porciani MC, Di Biase L, Padeletti L, Abbate R, Gensini GF. Relation of inflammatory status to major adverse cardiac events and reverse remodeling in patients undergoing cardiac resynchronization therapy. J Card Fail. 2007:207-210. [pmid: 17448418].
Niu HX, Hua W, Zhang S, Sun X, Chen KP, Wang FZ, Chen X. Optimized cardiac resynchronization therapy in patients with congestive heart failure. Chin Med J (Engl). 2007:605-607. [pmid: 17442212].
Penicka M, Vanderheyden M, Geelen P, Mortier L, Goethals M, Verstreken S, Karasek J, De Bruyne B, Bartunek J. Tissue Doppler predicts long-term clinical outcome after cardiac resynchronization therapy. Int J Cardiol. 2008:40-46. [pmid: 17383748].
Hoppe UC, Freemantle N, Cleland JG, Marijianowski M, Erdmann E. Effect of cardiac resynchronization on morbidity and mortality of diabetic patients with severe heart failure. Diabetes Care. 2007:722-724. [pmid: 17327349].
Gilliam FR 3rd, Singh JP, Mullin CM, McGuire M, Chase KJ. Prognostic value of heart rate variability footprint and standard deviation of average 5-minute intrinsic R-R intervals for mortality in cardiac resynchronization therapy patients. J Electrocardiol. 2007:336-342. [pmid: 17320897].
Ypenburg C, Roes SD, Bleeker GB, Kaandorp TA, de Roos A, Schalij MJ, van der Wall EE, Bax JJ. Effect of total scar burden on contrast-enhanced magnetic resonance imaging on response to cardiac resynchronization therapy. Am J Cardiol. 2007:657-660. [pmid: 17317367].
Becker M, Franke A, Breithardt OA, Ocklenburg C, Kaminski T, Kramann R, Knackstedt C, Stellbrink C, Hanrath P, Schauerte P, Hoffmann R. Impact of left ventricular lead position on the efficacy of cardiac resynchronisation therapy: a two-dimensional strain echocardiography study. Heart. 2007:1197-1203. [pmid: 17309913].
Capasso F, Giunta A, De Simone A, Turco P, La Rocca V, Grimaldi MG, Iuliano A, Stabile G. Acute left ventricular dyssynchrony improvement predicts long-term benefit from cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2007:S62-S65. [pmid: 17302720].
Eder V, Fauchier L, Courtehoux M, Bonnet P, Babuty D. Segmental wall motion abnormality analyzed by equilibrium radionuclide angiography and improvement in ventricular function by cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2007:S58-S61. [pmid: 17302719].
Tada H, Toide H, Okaniwa H, Higuchi R, Nakajima T, Utsugi R, Hashimoto T, Miyaji K, Kaseno K, Tadokoro K, Naito S, Nogami A, Oshima S, Taniguchi K. Maximum ventricular dyssynchrony predicts clinical improvement and reverse remodeling during cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2007:S13-S18. [pmid: 17302689].
Gilliam FR 3rd, Kaplan AJ, Black J, Chase KJ, Mullin CM. Changes in heart rate variability, quality of life, and activity in cardiac resynchronization therapy patients: results of the HF-HRV registry. Pacing Clin Electrophysiol. 2007:56-64. [pmid: 17241316].
Fung JW, Chan JY, Yip GW, Chan HC, Chan WW, Zhang Q, Yu CM. Effect of left ventricular endocardial activation pattern on echocardiographic and clinical response to cardiac resynchronization therapy. Heart. 2007:432-437. [pmid: 17237127].
Lellouche N, De Diego C, Cesario DA, Vaseghi M, Horowitz BN, Mahajan A, Wiener I, Boyle NG, Fonarow GC, Shivkumar K. Usefulness of preimplantation B-type natriuretic peptide level for predicting response to cardiac resynchronization therapy. Am J Cardiol. 2007:242-246. [pmid: 17223426].
Soliman OI, Theuns DA, Geleijnse ML, Anwar AM, Nemes A, Caliskan K, Vletter WB, Jordaens LJ, Cate FJ. Spectral pulsed-wave tissue Doppler imaging lateral-to-septal delay fails to predict clinical or echocardiographic outcome after cardiac resynchronization therapy. Europace. 2007:113-118. [pmid: 17218390].
Nagele H, Hashagen S, Azizi M, Behrens S, Castel MA. Long-term hemodynamic benefit of biventricular pacing depending on coronary sinus lead position. Herzschrittmacherther Elektrophysiol. 2006:185-190. [pmid: 17211748].
Jansen AH, Peels KH, Bracke F, van Dantzig JM, Meijer A, van der Voort PH, van Gelder B, Korsten HH, van Hemel NM. Relation of isovolumic times after cardiac resynchronization therapy to improvement in exercise capacity. Am J Cardiol. 2007:75-78. [pmid: 17196466].
Bleeker GB, Schalij MJ, Boersma E, Holman ER, Steendijk P, van der Wall EE, Bax JJ. Relative merits of M-mode echocardiography and tissue Doppler imaging for prediction of response to cardiac resynchronization therapy in patients with heart failure secondary to ischemic or idiopathic dilated cardiomyopathy. Am J Cardiol. 2007:68-74. [pmid: 17196465].
Inoue N, Takahashi N, Ishikawa T, Sumita S, Kobayashi T, Matsushita K, Matsumoto K, Taima M, Shimura M, Uchino K, Kimura K, Inoue T, Umemura S. Reverse perfusion-metabolism mismatch predicts good prognosis in patients undergoing cardiac resynchronization therapy: a pilot study. Circ J. 2007:126-131. [pmid: 17186990].
Fung JW, Szeto CC, Chan JY, Zhang Q, Chan HC, Yip GW, Yu CM. Prognostic value of renal function in patients with cardiac resynchronization therapy. Int J Cardiol. 2007:10-16. [pmid: 17174419].
Gasparini M, Lunati M, Santini M, Tritto M, Curnis A, Bocchiardo M, Vincenti A, Pistis G, Valsecchi S, Denaro A. Long-term survival in patients treated with cardiac resynchronization therapy: a 3-year follow-up study from the InSync/InSync ICD Italian Registry. Pacing Clin Electrophysiol. 2006:S2-S10. [pmid: 17169128].
Saxon LA, Bristow MR, Boehmer J, Krueger S, Kass DA, De Marco T, Carson P, DiCarlo L, Feldman AM, Galle E, Ecklund F. Predictors of sudden cardiac death and appropriate shock in the Comparison of Medical Therapy, Pacing, and Defibrillation in Heart Failure (COMPANION) Trial. Circulation. 2006:2766-2772. [pmid: 17159063].
Ypenburg C, Schalij MJ, Bleeker GB, Steendijk P, Boersma E, Dibbets-Schneider P, Stokkel MP, van der Wall EE, Bax JJ. Impact of viability and scar tissue on response to cardiac resynchronization therapy in ischaemic heart failure patients. Eur Heart J. 2007:33-41. [pmid: 17121757].
White JA, Yee R, Yuan X, Krahn A, Skanes A, Parker M, Klein G, Drangova M. Delayed enhancement magnetic resonance imaging predicts response to cardiac resynchronization therapy in patients with intraventricular dyssynchrony. J Am Coll Cardiol. 2006:1953-1960. [pmid: 17112984].
Singh JP, Fan D, Heist EK, Alabiad CR, Taub C, Reddy V, Mansour M, Picard MH, Ruskin JN, Mela T. Left ventricular lead electrical delay predicts response to cardiac resynchronization therapy. Heart Rhythm. 2006:1285-1292. [pmid: 17074633].
Lewicka-Nowak E, Dabrowska-Kugacka A, Faran A, Kutarski A, Wilczek R, Swiatecka G, Raczak G. Biventricular pacing demonstrates similar effects in elderly and younger patients with advanced heart failure in the mid-term follow-up. Kardiol Pol. 2006:975-983. discussion 984-5. [pmid: 17054029].
Delgado RM, Palanichamy N, Radovancevic R, Vrtovec B, Radovancevic B. Brain natriuretic peptide levels and response to cardiac resynchronization therapy in heart failure patients. Congest Heart Fail. 2006:250-253. [pmid: 17033272].
van Campen CM, Visser FC, van der Weerdt AP, Knaapen P, Comans EF, Lammertsma AA, de Cock CC, Visser CA. FDG PET as a predictor of response to resynchronisation therapy in patients with ischaemic cardiomyopathy. Eur J Nucl Med Mol Imaging. 2007:309-315. [pmid: 17021810].
Santos JF, Parreira L, Madeira J, Seixo F, Mendes L, Lopes C, Venancio J, Lourenco J, Caetano F, Ines L, Mendes M. Predictors of response to cardiac resynchronization therapy--importance of left ventricular dyssynchrony. Rev Port Cardiol. 2006:569-581. [pmid: 17019976].
Ypenburg C, Schalij MJ, Bleeker GB, Steendijk P, Boersma E, Dibbets-Schneider P, Stokkel MP, van der Wall EE, Bax JJ. Extent of viability to predict response to cardiac resynchronization therapy in ischemic heart failure patients. J Nucl Med. 2006:1565-1570. [pmid: 17015888].
Cannesson M, Tanabe M, Suffoletto MS, Schwartzman D, Gorcsan J 3rd. Velocity vector imaging to quantify ventricular dyssynchrony and predict response to cardiac resynchronization therapy. Am J Cardiol. 2006:949-953. [pmid: 16996881].
Hua W, Niu HX, Wang FZ, Zhang S, Chen KP, Chen X. Short-term effect of cardiac resynchronization therapy in patients with ischaemic or nonischaemic cardiomyopathy. Chin Med J (Engl). 2006:1507-1510. [pmid: 16996003].
Moak JP, Hasbani K, Ramwell C, Freedenberg V, Berger JT, DiRusso G, Callahan P. Dilated cardiomyopathy following right ventricular pacing for AV block in young patients: resolution after upgrading to biventricular pacing systems. J Cardiovasc Electrophysiol. 2006:1068-1071. [pmid: 16989648].
Fung JW, Zhang Q, Yip GW, Chan JY, Chan HC, Yu CM. Effect of cardiac resynchronization therapy in patients with moderate left ventricular systolic dysfunction and wide QRS complex: a prospective study. J Cardiovasc Electrophysiol. 2006:1288-1292. [pmid: 16987381].
Marai I, Gurevitz O, Carasso S, Nof E, Bar-Lev D, Luria D, Arbel Y, Freimark D, Feinberg MS, Eldar M, Glikson M. Improvement of congestive heart failure by upgrading of conventional to resynchronization pacemakers. Pacing Clin Electrophysiol. 2006:880-884. [pmid: 16923005].
Gasparini M, Auricchio A, Regoli F, Fantoni C, Kawabata M, Galimberti P, Pini D, Ceriotti C, Gronda E, Klersy C, Fratini S, Klein HH. Four-year efficacy of cardiac resynchronization therapy on exercise tolerance and disease progression: the importance of performing atrioventricular junction ablation in patients with atrial fibrillation. J Am Coll Cardiol. 2006:734-743. [pmid: 16904542].
Lappegard KT, Bjornstad H. Anti-inflammatory effect of cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2006:753-758. [pmid: 16884512].
Duncan AM, Lim E, Clague J, Gibson DG, Henein MY. Comparison of segmental and global markers of dyssynchrony in predicting clinical response to cardiac resynchronization. Eur Heart J. 2006:2426-2432. [pmid: 16882676].
Ypenburg C, van Erven L, Bleeker GB, Bax JJ, Bootsma M, Wijffels MC, van der Wall EE, Schalij MJ. Benefit of combined resynchronization and defibrillator therapy in heart failure patients with and without ventricular arrhythmias. J Am Coll Cardiol. 2006:464-470. [pmid: 16875970].
Akyol A, Alper AT, Cakmak N, Hasdemir H, Eksik A, Oguz E, Erdinler I, Ulufer FT, Gurkan K. Long-term effects of cardiac resynchronization therapy on heart rate and heart rate variability. Tohoku J Exp Med. 2006:337-346. [pmid: 16864956].
Najem B, Unger P, Preumont N, Jansens JL, Houssiere A, Pathak A, Xhaet O, Gabriel L, Friart A, De Roy L, Vandenbossche JL, van de Borne P. Sympathetic control after cardiac resynchronization therapy: responders versus nonresponders. Am J Physiol Heart Circ Physiol. 2006:H2647-H2652. [pmid: 16844919].
Arzola-Castaner D, Taub C, Kevin Heist E, Fan D, Haelewyn K, Mela T, Picard MH, Ruskin JN, Singh JP. Left ventricular lead proximity to an akinetic segment and impact on outcome of cardiac resynchronization therapy. J Cardiovasc Electrophysiol. 2006:623-627. [pmid: 16836711].
Glick A, Michowitz Y, Keren G, George J. Neurohormonal and inflammatory markers as predictors of short-term outcome in patients with heart failure and cardiac resynchronization therapy. Isr Med Assoc J. 2006:391-395. [pmid: 16833167].
Porciani MC, Lilli A, Macioce R, Cappelli F, Demarchi G, Pappone A, Ricciardi G, Padeletti L. Utility of a new left ventricular asynchrony index as a predictor of reverse remodelling after cardiac resynchronization therapy. Eur Heart J. 2006:1818-1823. [pmid: 16818457].
Hoppe UC, Casares JM, Eiskjaer H, Hagemann A, Cleland JG, Freemantle N, Erdmann E. Effect of cardiac resynchronization on the incidence of atrial fibrillation in patients with severe heart failure. Circulation. 2006:18-25. [pmid: 16801461].
Fung JW, Chan JY, Kum LC, Chan HC, Yip GW, Zhang Q, Yu CM. Suboptimal medical therapy in patients with systolic heart failure is associated with less improvement by cardiac resynchronization therapy. Int J Cardiol. 2007:214-219. [pmid: 16797091].
Tedrow UB, Kramer DB, Stevenson LW, Stevenson WG, Baughman KL, Epstein LM, Lewis EF. Relation of right ventricular peak systolic pressure to major adverse events in patients undergoing cardiac resynchronization therapy. Am J Cardiol. 2006:1737-1740. [pmid: 16765124].
Heist EK, Taub C, Fan D, Arzola-Castaner D, Alabiad CR, Reddy VY, Mansour M, Mela T, Picard MH, Ruskin JN, Singh JP. Usefulness of a novel &quot;response score&quot; to predict hemodynamic and clinical outcome from cardiac resynchronization therapy. Am J Cardiol. 2006:1732-1736. [pmid: 16765123].
Higuchi K, Toyama T, Tada H, Naito S, Ohshima S, Kurabayashi M. Usefulness of biventricular pacing to improve cardiac symptoms, exercise capacity and sympathetic nerve activity in patients with moderate to severe chronic heart failure. Circ J. 2006:703-709. [pmid: 16723791].
Witte KK, Pipes RR, Nanthakumar K, Parker JD. Biventricular pacemaker upgrade in previously paced heart failure patients--improvements in ventricular dyssynchrony. J Card Fail. 2006:199-204. [pmid: 16624685].
Yu CM, Zhang Q, Chan YS, Chan CK, Yip GW, Kum LC, Wu EB, Lee PW, Lam YY, Chan S, Fung JW. Tissue Doppler velocity is superior to displacement and strain mapping in predicting left ventricular reverse remodelling response after cardiac resynchronisation therapy. Heart. 2006:1452-1456. [pmid: 16621873].
Boriani G, Regoli F, Saporito D, Martignani C, Toselli T, Biffi M, Francolini G, Diemberger I, Bacchi L, Rapezzi C, Ferrari R, Branzi A. Neurohormones and inflammatory mediators in patients with heart failure undergoing cardiac resynchronization therapy: time courses and prediction of response. Peptides. 2006:1776-1786. [pmid: 16621149].
Konstantino Y, Iakobishvili Z, Arad O, Ben-Gal T, Kusniec J, Mazur A, Porter A, Strasberg B, Battler A, Hasdai D. Urgent cardiac resynchronization therapy in patients with decompensated chronic heart failure receiving inotropic therapy. A case series. Cardiology. 2006:59-62. [pmid: 16612071].
Mele D, Pasanisi G, Capasso F, De Simone A, Morales MA, Poggio D, Capucci A, Tabacchi G, Sallusti L, Ferrari R. Left intraventricular myocardial deformation dyssynchrony identifies responders to cardiac resynchronization therapy in patients with heart failure. Eur Heart J. 2006:1070-1078. [pmid: 16574689].
James KB, Militello M, Barbara G, Wilkoff BL. Biventricular pacing for heart failure patients on inotropic support: a review of 38 consecutive cases. Tex Heart Inst J. 2006:19-22. [pmid: 16572863].
Pires LA, Abraham WT, Young JB, Johnson KM. Clinical predictors and timing of New York Heart Association class improvement with cardiac resynchronization therapy in patients with advanced chronic heart failure: results from the Multicenter InSync Randomized Clinical Evaluation (MIRACLE) and Multicenter InSync ICD Randomized Clinical Evaluation (MIRACLE-ICD) trials. Am Heart J. 2006:837-843. [pmid: 16569543].
Eldadah ZA, Rosen B, Hay I, Edvardsen T, Jayam V, Dickfeld T, Meininger GR, Judge DP, Hare J, Lima JB, Calkins H, Berger RD. The benefit of upgrading chronically right ventricle-paced heart failure patients to resynchronization therapy demonstrated by strain rate imaging. Heart Rhythm. 2006:435-442. [pmid: 16567291].
Da Costa A, Thevenin J, Roche F, Faure E, Romeyer-Bouchard C, Messier M, Convert G, Barthelemy JC, Isaaz K. Prospective validation of stress echocardiography as an identifier of cardiac resynchronization therapy responders. Heart Rhythm. 2006:406-413. [pmid: 16567286].
Kubanek M, Malek I, Bytesnik J, Fridl P, Riedlbauchova L, Karasova L, Lanska V, Kautzner J. Decrease in plasma B-type natriuretic peptide early after initiation of cardiac resynchronization therapy predicts clinical improvement at 12 months. Eur J Heart Fail. 2006:832-840. [pmid: 16546444].
Harada M, Osaka T, Yokoyama E, Takemoto Y, Ito A, Kodama I. Biventricular pacing has an advantage over left ventricular epicardial pacing alone to minimize proarrhythmic perturbation of repolarization. J Cardiovasc Electrophysiol. 2006:151-156. [pmid: 16533252].
Steendijk P, Tulner SA, Bax JJ, Oemrawsingh PV, Bleeker GB, van Erven L, Putter H, Verwey HF, van der Wall EE, Schalij MJ. Hemodynamic effects of long-term cardiac resynchronization therapy: analysis by pressure-volume loops. Circulation. 2006:1295-1304. [pmid: 16520415].
Vidal B, Sitges M, Marigliano A, Diaz-Infante E, Azqueta M, Tamborero D, Macias A, Roig E, Brugada J, Pare C, Mont L. Relation of response to cardiac resynchronization therapy to left ventricular reverse remodeling. Am J Cardiol. 2006:876-881. [pmid: 16516593].
Pitzalis MV, Iacoviello M, Di Serio F, Romito R, Guida P, De Tommasi E, Luzzi G, Anaclerio M, Varraso L, Forleo C, Pansini N. Prognostic value of brain natriuretic peptide in the management of patients receiving cardiac resynchronization therapy. Eur J Heart Fail. 2006:509-514. [pmid: 16503416].
Waggoner AD, Rovner A, de las Fuentes L, Faddis MN, Gleva MJ, Sawhney N, Davila-Roman VG. Clinical outcomes after cardiac resynchronization therapy: importance of left ventricular diastolic function and origin of heart failure. J Am Soc Echocardiogr. 2006:307-313. [pmid: 16500494].
Bleeker GB, Kaandorp TA, Lamb HJ, Boersma E, Steendijk P, de Roos A, van der Wall EE, Schalij MJ, Bax JJ. Effect of posterolateral scar tissue on clinical and echocardiographic improvement after cardiac resynchronization therapy. Circulation. 2006:969-976. [pmid: 16476852].
Suffoletto MS, Dohi K, Cannesson M, Saba S, Gorcsan J 3rd. Novel speckle-tracking radial strain from routine black-and-white echocardiographic images to quantify dyssynchrony and predict response to cardiac resynchronization therapy. Circulation. 2006:960-968. [pmid: 16476850].
Mangiavacchi M, Gasparini M, Faletra F, Klersy C, Morenghi E, Galimberti P, Genovese L, Regoli F, De Chiara F, Bragato R, Andreuzzi B, Pini D, Gronda E. Clinical predictors of marked improvement in left ventricular performance after cardiac resynchronization therapy in patients with chronic heart failure. Am Heart J. 2006:477.e1-477.e6. [pmid: 16442917].
Bleeker GB, Bax JJ, Fung JW, van der Wall EE, Zhang Q, Schalij MJ, Chan JY, Yu CM. Clinical versus echocardiographic parameters to assess response to cardiac resynchronization therapy. Am J Cardiol. 2006:260-263. [pmid: 16442375].
de Sisti A, Toussaint JF, Lavergne T, Ollitrault J, Abergel E, Paziaud O, Ait Said M, Sader R, LE Heuzey JY, Guize L. Determinants of mortality in patients undergoing cardiac resynchronization therapy: baseline clinical, echocardiographic, and angioscintigraphic evaluation prior to resynchronization. Pacing Clin Electrophysiol. 2005:1260-1270. [pmid: 16403157].
Sakamoto S, Matsubara J, Nagayoshi Y, Nishizawa H, Takeuchi K, Nonaka T. Clinical evaluation of combination therapy for biventricular pacing after cardiac surgery in patients with intractable heart failure. Ann Thorac Cardiovasc Surg. 2005:408-412. [pmid: 16401992].
Porciani MC, Macioce R, Demarchi G, Chiostri M, Musilli N, Cappelli F, Lilli A, Ricciardi G, Padeletti L. Effects of cardiac resynchronization therapy on the mechanisms underlying functional mitral regurgitation in congestive heart failure. Eur J Echocardiogr. 2006:31-39. [pmid: 16378918].
Schlosshan D, Barker D, Pepper C, Williams G, Morley C, Tan LB. CRT improves the exercise capacity and functional reserve of the failing heart through enhancing the cardiac flow- and pressure-generating capacity. Eur J Heart Fail. 2006:515-521. [pmid: 16377239].
Cozma D, Kalifa J, Pescariu S, Lighezan D, Deharo JC, Mornos C, Djiane P, Luca CT, Petrescu L, Dragulescu SI. Global myocardial index in patients with multisite pacing. Rom J Intern Med. 2004:521-531. [pmid: 16366129].
Tse HF, Siu CW, Lee KL, Fan K, Chan HW, Tang MO, Tsang V, Lee SW, Lau CP. The incremental benefit of rate-adaptive pacing on exercise performance during cardiac resynchronization therapy. J Am Coll Cardiol. 2005:2292-2297. [pmid: 16360061].
Bleeker GB, Schalij MJ, Nihoyannopoulos P, Steendijk P, Molhoek SG, van Erven L, Bootsma M, Holman ER, van der Wall EE, Bax JJ. Left ventricular dyssynchrony predicts right ventricular remodeling after cardiac resynchronization therapy. J Am Coll Cardiol. 2005:2264-2269. [pmid: 16360056].
Waggoner AD, Faddis MN, Gleva MJ, de las Fuentes L, Davila-Roman VG. Improvements in left ventricular diastolic function after cardiac resynchronization therapy are coupled to response in systolic performance. J Am Coll Cardiol. 2005:2244-2249. [pmid: 16360053].
Marcus GM, Rose E, Viloria EM, Schafer J, De Marco T, Saxon LA, Foster E. Septal to posterior wall motion delay fails to predict reverse remodeling or clinical improvement in patients undergoing cardiac resynchronization therapy. J Am Coll Cardiol. 2005:2208-2214. [pmid: 16360048].
Porciani MC, Valsecchi S, Demarchi G, Colella A, Michelucci A, Pieragnoli P, Musilli N, Gensini GF, Padeletti L. Evolution and prognostic significance of diastolic filling pattern in cardiac resynchronization therapy. Int J Cardiol. 2006:322-328. [pmid: 16318886].
D'Ascia C, Cittadini A, Monti MG, Riccio G, Sacca L. Effects of biventricular pacing on interstitial remodelling, tumor necrosis factor-alpha expression, and apoptotic death in failing human myocardium. Eur Heart J. 2006:201-206. [pmid: 16291773].
Hummel JP, Lindner JR, Belcik JT, Ferguson JD, Mangrum JM, Bergin JD, Haines DE, Lake DE, DiMarco JP, Mounsey JP. Extent of myocardial viability predicts response to biventricular pacing in ischemic cardiomyopathy. Heart Rhythm. 2005:1211-1217. [pmid: 16253911].
Brandt RR, Reiner C, Arnold R, Sperzel J, Pitschner HF, Hamm CW. Contractile response and mitral regurgitation after temporary interruption of long-term cardiac resynchronization therapy. Eur Heart J. 2006:187-192. [pmid: 16223745].
Heinke M, Surber R, Kuhnert H, Dannberg G, Schwarz G, Figulla HR. Transoesophageal left ventricular pacing in heart failure patients with permanent right ventricular pacing. Europace. 2005:617-620. [pmid: 16216766].
De Maria E, Gallo P, Damiano M, Scognamiglio G, De Simone C, Nilo S, Guarini P, Mascioli G, Curnis A. Predictive parameters of left ventricular reverse remodeling in response to cardiac resynchronization therapy in patients with severe congestive heart failure. Ital Heart J. 2005:734-739. [pmid: 16212075].
Najem B, Preumont N, Unger P, Jansens JL, Houssiere A, Ciarka A, Stoupel E, Degaute JP, van de Borne P. Sympathetic nerve activity after thoracoscopic cardiac resynchronization therapy in congestive heart failure. J Card Fail. 2005:529-533. [pmid: 16198249].
Vanderheyden M, De Backer T, Rivero-Ayerza M, Geelen P, Bartunek J, Verstreken S, De Zutter M, Goethals M. Tailored echocardiographic interventricular delay programming further optimizes left ventricular performance after cardiac resynchronization therapy. Heart Rhythm. 2005:1066-1072. [pmid: 16188583].
Macioce R, Cappelli F, Demarchi G, Lilli A, Ricciardi G, Pieragnoli P, Colella A, Michelucci A, Porciani MC, Padeletti L. Resynchronization of mitral valve annular segments reduces functional mitral regurgitation in cardiac resynchronization therapy. Minerva Cardioangiol. 2005:329-333. [pmid: 16177677].
Burri H, Sunthorn H, Somsen A, Zaza S, Fleury E, Shah D, Righetti A. Optimizing sequential biventricular pacing using radionuclide ventriculography. Heart Rhythm. 2005:960-965. [pmid: 16171751].
Bleeker GB, Schalij MJ, Molhoek SG, Boersma E, Steendijk P, van der Wall EE, Bax JJ. Comparison of effectiveness of cardiac resynchronization therapy in patients &lt;70 versus &gt; or =70 years of age. Am J Cardiol. 2005:420-422. [pmid: 16054473].
Molhoek SG, Bax JJ, Bleeker GB, Holman ER, Van Erven L, Bootsma M, Boersma E, Steendijk P, Van Der Wall EE, Schalij MJ. Long-term follow-up of cardiac resynchronization therapy in patients with end-stage heart failure. J Cardiovasc Electrophysiol. 2005:701-707. [pmid: 16050826].
Tse HF, Lee KL, Wan SH, Yu Y, Hoersch W, Pastore J, Zhu Q, Kenknight B, Spinelli J, Lau CP. Area of left ventricular regional conduction delay and preserved myocardium predict responses to cardiac resynchronization therapy. J Cardiovasc Electrophysiol. 2005:690-695. [pmid: 16050824].
Agacdiken A, Vural A, Ural D, Sahin T, Kozdag G, Kahraman G, Bildirici U, Ural E, Komsuoglu B. Effect of cardiac resynchronization therapy on left ventricular diastolic filling pattern in responder and nonresponder patients. Pacing Clin Electrophysiol. 2005:654-660. [pmid: 16008800].
Gabor JY, Newman DA, Barnard-Roberts V, Korley V, Mangat I, Dorian P, Hanly PJ. Improvement in Cheyne-Stokes respiration following cardiac resynchronisation therapy. Eur Respir J. 2005:95-100. [pmid: 15994394].
Yu CM, Abraham WT, Bax J, Chung E, Fedewa M, Ghio S, Leclercq C, Leon AR, Merlino J, Nihoyannopoulos P, Notabartolo D, Sun JP, Tavazzi L. Predictors of response to cardiac resynchronization therapy (PROSPECT)--study design. Am Heart J. 2005:600-605. [pmid: 15990740].
Kies P, Bax JJ, Molhoek SG, Bleeker GB, Boersma E, Steendijk P, van der Wall EE, Schalij MJ. Comparison of effectiveness of cardiac resynchronization therapy in patients with versus without diabetes mellitus. Am J Cardiol. 2005:108-111. [pmid: 15979446].
Bomma C, Dalal D, Tandri H, Prakasa K, Nasir K, Roguin A, Tichnell C, James C, Lima JA, Calkins H, Bluemke DA. Regional differences in systolic and diastolic function in arrhythmogenic right ventricular dysplasia/cardiomyopathy using magnetic resonance imaging. Am J Cardiol. 2005:1507-1511. [pmid: 15950585].
Berger T, Hanser F, Hintringer F, Poelzl G, Fischer G, Modre R, Tilg B, Pachinger O, Roithinger FX. Effects of cardiac resynchronization therapy on ventricular repolarization in patients with congestive heart failure. J Cardiovasc Electrophysiol. 2005:611-617. [pmid: 15946359].
Vural A, Agacdiken A, Ural D, Sahin T, Kozdag G, Kahraman G, Ural E, Akbas H, Suzer K, Komsuoglu B. Effect of cardiac resynchronization therapy on left atrial appendage function and pulmonary venous flow pattern. Int J Cardiol. 2005:103-109. [pmid: 15939105].
Ferro A, Duilio C, Santomauro M, Salvatore M, Cuocolo A. Haemodynamic effects of dual-chamber pacing versus ventricular pacing during a walk test in patients with depressed or normal left ventricular function. Eur J Nucl Med Mol Imaging. 2005:1075-1080. [pmid: 15891919].
Bernheim A, Ammann P, Sticherling C, Burger P, Schaer B, Brunner-La Rocca HP, Eckstein J, Kiencke S, Kaiser C, Linka A, Buser P, Pfisterer M, Osswald S. Right atrial pacing impairs cardiac function during resynchronization therapy: acute effects of DDD pacing compared to VDD pacing. J Am Coll Cardiol. 2005:1482-1487. [pmid: 15862423].
Davis DR, Krahn AD, Tang AS, Lemery R, Green MS, Gollob M, Yee R, Skanes AC, Klein GJ, Birnie DH. Long-term outcome of cardiac resynchronization therapy in patients with severe congestive heart failure. Can J Cardiol. 2005:413-417. [pmid: 15861258].
Kies P, Bax JJ, Molhoek SG, Bleeker GB, Zeppenfeld K, Bootsma M, van Erven L, Steendijk P, van der Wall EE, Schalij MJ. Effect of cardiac resynchronization therapy on inducibility of ventricular tachyarrhythmias in cardiac arrest survivors with either ischemic or idiopathic dilated cardiomyopathy. Am J Cardiol. 2005:1111-1114. [pmid: 15842986].
Erol-Yilmaz A, Verberne HJ, Schrama TA, Hrudova J, De Winter RJ, Van Eck-Smit BL, De Bruin R, Bax JJ, Schalij MJ, Wilde AA, Tukkie R. Cardiac resynchronization induces favorable neurohumoral changes. Pacing Clin Electrophysiol. 2005:304-310. [pmid: 15826264].
Woo GW, Petersen-Stejskal S, Johnson JW, Conti JB, Aranda JA Jr, Curtis AB. Ventricular reverse remodeling and 6-month outcomes in patients receiving cardiac resynchronization therapy: analysis of the MIRACLE study. J Interv Card Electrophysiol. 2005:107-113. [pmid: 15744462].
Capasso F, Giunta A, Stabile G, Turco P, La Rocca V, Grimaldi G, De Simone A. Left ventricular functional recovery during cardiac resynchronization therapy: predictive role of asynchrony measured by strain rate analysis. Pacing Clin Electrophysiol. 2005:S1-S4. [pmid: 15683471].
Inoue N, Ishikawa T, Sumita S, Nakagawa T, Kobayashi T, Matsushita K, Matsumoto K, Ohkusu Y, Taima M, Kosuge M, Uchino K, Kimura K, Umemura S. Long-term follow-up of atrioventricular delay optimization in patients with biventricular pacing. Circ J. 2005:201-204. [pmid: 15671613].
Tada H, Toide H, Naito S, Kurosaki K, Ito S, Miyaji K, Yamada M, Okaniwa H, Kobayashi Y, Maruyama H, Higuchi R, Nogami A, Oshima S, Taniguchi K. Tissue Doppler imaging and strain Doppler imaging as modalities for predicting clinical improvement in patients receiving biventricular pacing. Circ J. 2005:194-200. [pmid: 15671612].
Zanon F, Aggio S, Baracca E, Bilato C, Corbucci G, Rigatelli G, Zonzin P. Reduced mitral regurgitation in heart failure patients submitted to cardiac resynchronization therapy: a short-term prospective study. Ital Heart J. 2004:826-830. [pmid: 15633437].
Barbieri A, Bursi F, Bonatti S, Coppi F, Zanasi V, Reggianini L, Casali E, Malavasi VL, Modena MG. Evidence of reverse remodeling after long-term biventricular stimulation for resynchronization in patients with wide QRS selected on the basis of echocardiographic electromechanical delays. Ital Heart J. 2004:818-825. [pmid: 15633436].
Aranda JM Jr, Conti JB, Johnson JW, Petersen-Stejskal S, Curtis AB. Cardiac resynchronization therapy in patients with heart failure and conduction abnormalities other than left bundle-branch block: analysis of the Multicenter InSync Randomized Clinical Evaluation (MIRACLE). Clin Cardiol. 2004:678-682. [pmid: 15628109].
Bordachar P, Lafitte S, Reuter S, Garrigue S, Sanders P, Roudaut R, Jais P, Haissaguerre M, Clementy J. Biventricular pacing and left ventricular pacing in heart failure: similar hemodynamic improvement despite marked electromechanical differences. J Cardiovasc Electrophysiol. 2004:1342-1347. [pmid: 15610275].
Molhoek SG, Bax JJ, Bleeker GB, Boersma E, van Erven L, Steendijk P, van der Wall EE, Schalij MJ. Comparison of response to cardiac resynchronization therapy in patients with sinus rhythm versus chronic atrial fibrillation. Am J Cardiol. 2004:1506-1509. [pmid: 15589005].
Lancellotti P, Melon P, Sakalihasan N, Waleffe A, Dubois C, Bertholet M, Pierard LA. Effect of cardiac resynchronization therapy on functional mitral regurgitation in heart failure. Am J Cardiol. 2004:1462-1465. [pmid: 15566929].
Schuster P, Faerestrand S, Ohm OJ. Reverse remodelling of systolic left ventricular contraction pattern by long term cardiac resynchronisation therapy: colour Doppler shows resynchronisation. Heart. 2004:1411-1416. [pmid: 15547015].
Reynolds MR, Joventino LP, Josephson ME. Relationship of baseline electrocardiographic characteristics with the response to cardiac resynchronization therapy for heart failure. Pacing Clin Electrophysiol. 2004:1513-1518. [pmid: 15546306].
Dixon LJ, Murtagh JG, Richardson SG, Chew EW. Reduction in hospitalization rates following cardiac resynchronisation therapy in cardiac failure: experience from a single centre. Europace. 2004:586-589. [pmid: 15519262].
Bax JJ, Bleeker GB, Marwick TH, Molhoek SG, Boersma E, Steendijk P, van der Wall EE, Schalij MJ. Left ventricular dyssynchrony predicts response and prognosis after cardiac resynchronization therapy. J Am Coll Cardiol. 2004:1834-1840. [pmid: 15519016].
Rossillo A, Verma A, Saad EB, Corrado A, Gasparini G, Marrouche NF, Golshayan AR, McCurdy R, Bhargava M, Khaykin Y, Burkhardt JD, Martin DO, Wilkoff BL, Saliba WI, Schweikert RA, Raviele A, Natale A. Impact of coronary sinus lead position on biventricular pacing: mortality and echocardiographic evaluation during long-term follow-up. J Cardiovasc Electrophysiol. 2004:1120-1125. [pmid: 15485432].
Yu CM, Fung JW, Chan CK, Chan YS, Zhang Q, Lin H, Yip GW, Kum LC, Kong SL, Zhang Y, Sanderson JE. Comparison of efficacy of reverse remodeling and clinical improvement for relatively narrow and wide QRS complexes after cardiac resynchronization therapy for heart failure. J Cardiovasc Electrophysiol. 2004:1058-1065. [pmid: 15363081].
Vinereanu D, Bleasdale R, Turner M, Frenneaux MP, Fraser AG. Comparison of left ventricular-biventricular pacing on ventricular synchrony, mitral regurgitation, and global left ventricular function in patients with severe chronic heart failure. Am J Cardiol. 2004:519-521. [pmid: 15325945].
Valls-Bertault V, Fatemi M, Gilard M, Pennec PY, Etienne Y, Blanc JJ. Assessment of upgrading to biventricular pacing in patients with right ventricular pacing and congestive heart failure after atrioventricular junctional ablation for chronic atrial fibrillation. Europace. 2004:438-443. [pmid: 15294269].
Knuuti J, Sundell J, Naum A, Engblom E, Koistinen J, Ylitalo A, Stolen KQ, Kalliokoski R, Nekolla SG, Bax KE, Airaksinen KE. Assessment of right ventricular oxidative metabolism by PET in patients with idiopathic dilated cardiomyopathy undergoing cardiac resynchronization therapy. Eur J Nucl Med Mol Imaging. 2004:1592-1598. [pmid: 15290120].
Kies P, Bax JJ, Molhoek SG, Bleeker GB, Zeppenfeld K, Bootsma M, St John Sutton M, van Erven L, van der Wall EE, Schalij MJ. Effect of left ventricular remodeling after cardiac resynchronization therapy on frequency of ventricular arrhythmias. Am J Cardiol. 2004:130-132. [pmid: 15219525].
Bleeker GB, Schalij MJ, Molhoek SG, Verwey HF, Holman ER, Boersma E, Steendijk P, Van Der Wall EE, Bax JJ. Relationship between QRS duration and left ventricular dyssynchrony in patients with end-stage heart failure. J Cardiovasc Electrophysiol. 2004:544-549. [pmid: 15149423].
Turner MS, Bleasdale RA, Vinereanu D, Mumford CE, Paul V, Fraser AG, Frenneaux MP. Electrical and mechanical components of dyssynchrony in heart failure patients with normal QRS duration and left bundle-branch block: impact of left and biventricular pacing. Circulation. 2004:2544-2549. [pmid: 15148267].
Takemoto M, Sakamoto M, Kawagoe J, Goto K, Baba H, Noma M, Origuchi H, Yoshimura H, Sese A, Yamamoto H. Effect of biventricular pacing therapy in patients with dilated cardiomyopathy with severe congestive heart failure. Jpn J Thorac Cardiovasc Surg. 2004:175-180. [pmid: 15141704].
Riedlbauchova L, Fridl P, Kautzner J, Peichl P. Performance of left ventricular versus biventricular pacing in chronic heart failure assessed by stress echocardiography. Pacing Clin Electrophysiol. 2004:626-631. [pmid: 15125719].
Molhoek SG, Bax JJ, van Erven L, Bootsma M, Boersma E, Steendijk P, van der Wall EE, Schalij MJ. Comparison of benefits from cardiac resynchronization therapy in patients with ischemic cardiomyopathy versus idiopathic dilated cardiomyopathy. Am J Cardiol. 2004:860-863. [pmid: 15050489].
Sundell J, Engblom E, Koistinen J, Ylitalo A, Naum A, Stolen KQ, Kalliokoski R, Nekolla SG, Airaksinen KE, Bax JJ, Knuuti J. The effects of cardiac resynchronization therapy on left ventricular function, myocardial energetics, and metabolic reserve in patients with dilated cardiomyopathy and heart failure. J Am Coll Cardiol. 2004:1027-1033. [pmid: 15028362].
Molhoek SG, VAN Erven L, Bootsma M, Steendijk P, Van Der Wall EE, Schalij MJ. QRS duration and shortening to predict clinical response to cardiac resynchronization therapy in patients with end-stage heart failure. Pacing Clin Electrophysiol. 2004:308-313. [pmid: 15009855].
Vural A, Agacdiken A, Ural D, Sahin T, Kozdag G, Kahraman G, Ural E, Akbas H, Suzer K, Komsuoglu B. Effect of cardiac resynchronization therapy on left atrial reverse remodeling and spontaneous echo contrast. Tohoku J Exp Med. 2004:143-153. [pmid: 14998308].
Lafitte S, Garrigue S, Perron JM, Bordachar P, Reuter S, Jais P, Haissaguerre M, Clementy J, Roudaut R. Improvement of left ventricular wall synchronization with multisite ventricular pacing in heart failure: a prospective study using Doppler tissue imaging. Eur J Heart Fail. 2004:203-212. [pmid: 14984728].
Santos JF, Caetano F, Parreira L, Madeira J, Cardoso P, Fonseca N, Segurado F, Soares LN, Ines L. Tissue Doppler echocardiography for evaluation of patients with ventricular resynchronization therapy. Rev Port Cardiol. 2003:1363-1371. [pmid: 14768491].
Santos JF, Caetano F, Parreira L, Madeira J, Cardoso P, Fonseca N, Segurado F, Soares LN, Ines L. Effects of cardiac resynchronization therapy on right ventricular function--evaluation with tissue Doppler echocardiography. Rev Port Cardiol. 2003:1347-1355. [pmid: 14768490].
Cholewinski W, Tarkowska A, Kutarski A, Stefaniak B, Poniatowicz-Frasunek E, Oleszczak K. Effect of biventricular pacing on heart function evaluated by gated blood pool study in patients with end-stage heart failure. Nucl Med Rev Cent East Eur. 2002:155-157. [pmid: 14600876].
Toussaint JF, Lavergne T, Kerrou K, Froissart M, Ollitrault J, Darondel JM, Alonso C, Diebold B, Le Heuzey JY, Guize L, Paillard M. Basal asynchrony and resynchronization with biventricular pacing predict long-term improvement of LV function in heart failure patients. Pacing Clin Electrophysiol. 2003:1815-1823. [pmid: 12930495].
Makaryus AN, Arduini AD, Mallin J, Chung E, Kort S, Shi Q, Jadonath R, Mangion J. Echocardiographic features of patients with heart failure who may benefit from biventricular pacing. Echocardiography. 2003:217-223. [pmid: 12848658].
Varma C, O'Callaghan P, Rowland E, Mahon NG, Mckenna W, Camm AJ, Brecker SJ. Comparison between biventricular pacing and single site pacing in patients with poor ventricular function: a hemodynamic study. Pacing Clin Electrophysiol. 2003:551-558. [pmid: 12710313].
Gasparini M, Mantica M, Galimberti P, Coltorti F, Simonini S, Ceriotti C, Gronda E. Biventricular pacing via a persistent left superior vena cava: report of four cases. Pacing Clin Electrophysiol. 2003:192-196. [pmid: 12687811].
Gasparini M, Mantica M, Galimberti P, Genovese L, Pini D, Faletra F, Marchesina UL, Mangiavacchi M, Klersy C, Gronda E. Is the outcome of cardiac resynchronization therapy related to the underlying etiology?. Pacing Clin Electrophysiol. 2003:175-180. [pmid: 12687807].
Ohkusu Y, Takahashi N, Ishikawa T, Sumita S, Kobayashi T, Matsushita K, Yamakawa Y, Uchino K, Kimura K, Inoue T, Umemura S. Effect of biventricular pacing on myocardial glucose metabolism in patients with heart failure using fluoro-18-deoxyglucose positron emission tomography. Pacing Clin Electrophysiol. 2003:144-147. [pmid: 12687800].
Nielsen JC, Bottcher M, Jensen HK, Nielsen TT, Pedersen AK, Mortensen PT. Regional myocardial perfusion during chronic biventricular pacing and after acute change of the pacing mode in patients with congestive heart failure and bundle branch block treated with an atrioventricular sequential biventricular pacemaker. Eur J Heart Fail. 2003:179-186. [pmid: 12644010].
Sinha AM, Filzmaier K, Breithardt OA, Kunz D, Graf J, Markus KU, Hanrath P, Stellbrink C. Usefulness of brain natriuretic peptide release as a surrogate marker of the efficacy of long-term cardiac resynchronization therapy in patients with heart failure. Am J Cardiol. 2003:755-758. [pmid: 12633819].
Yu CM, Fung WH, Lin H, Zhang Q, Sanderson JE, Lau CP. Predictors of left ventricular reverse remodeling after cardiac resynchronization therapy for heart failure secondary to idiopathic dilated or ischemic cardiomyopathy. Am J Cardiol. 2003:684-688. [pmid: 12633798].
Breithardt OA, Sinha AM, Schwammenthal E, Bidaoui N, Markus KU, Franke A, Stellbrink C. Acute effects of cardiac resynchronization therapy on functional mitral regurgitation in advanced systolic heart failure. J Am Coll Cardiol. 2003:765-770. [pmid: 12628720].
Gilligan DM, Sargent D, Ponnathpur V, Dan D, Zakaib JS, Ellenbogen KA. Echocardiographic atrioventricular interval optimization in patients with dual-chamber pacemakers and symptomatic left ventricular systolic dysfunction. Am J Cardiol. 2003:629-631. [pmid: 12615281].
Izutani H, Quan KJ, Biblo LA, Gill IS. Biventricular pacing for congestive heart failure: early experience in surgical epicardial versus coronary sinus lead placement. Heart Surg Forum. 2002:E1-E6. discussion E1-6. [pmid: 12611737].
Popovic ZB, Grimm RA, Perlic G, Chinchoy E, Geraci M, Sun JP, Donal E, Xu XF, Greenberg NL, Wilkoff BL, Thomas JD. Noninvasive assessment of cardiac resynchronization therapy for congestive heart failure using myocardial strain and left ventricular peak power as parameters of myocardial synchrony and function. J Cardiovasc Electrophysiol. 2002:1203-1208. [pmid: 12521333].
Pitzalis MV, Iacoviello M, Romito R, Massari F, Rizzon B, Luzzi G, Guida P, Andriani A, Mastropasqua F, Rizzon P. Cardiac resynchronization therapy tailored by echocardiographic evaluation of ventricular asynchrony. J Am Coll Cardiol. 2002:1615-1622. [pmid: 12427414].
Sogaard P, Egeblad H, Kim WY, Jensen HK, Pedersen AK, Kristensen BO, Mortensen PT. Tissue Doppler imaging predicts improved systolic performance and reversed left ventricular remodeling during long-term cardiac resynchronization therapy. J Am Coll Cardiol. 2002:723-730. [pmid: 12204503].
Breithardt OA, Stellbrink C, Kramer AP, Sinha AM, Franke A, Salo R, Schiffgens B, Huvelle E, Auricchio A. Echocardiographic quantification of left ventricular asynchrony predicts an acute hemodynamic benefit of cardiac resynchronization therapy. J Am Coll Cardiol. 2002:536-545. [pmid: 12142123].
Pyatt JR, Somauroo JD, Jackson M, Grayson AD, Osula S, Aggarwal RK, Charles RG, Connelly DT. Long-term survival after permanent pacemaker implantation: analysis of predictors for increased mortality. Europace. 2002:113-119. [pmid: 12135241].
Kawaguchi M, Murabayashi T, Fetics BJ, Nelson GS, Samejima H, Nevo E, Kass DA. Quantitation of basal dyssynchrony and acute resynchronization from left or biventricular pacing by novel echo-contrast variability imaging. J Am Coll Cardiol. 2002:2052-2058. [pmid: 12084608].
Hamdan MH, Barbera S, Kowal RC, Page RL, Ramaswamy K, Joglar JA, Karimkhani V, Smith ML. Effects of resynchronization therapy on sympathetic activity in patients with depressed ejection fraction and intraventricular conduction delay due to ischemic or idiopathic dilated cardiomyopathy. Am J Cardiol. 2002:1047-1051. [pmid: 11988193].
Lehmann A, Lang J, Thaler E, Zeitler C, Weisse U, Boldt J. Considerations in patients undergoing implantation of a biventricular pacemaker. J Cardiothorac Vasc Anesth. 2002:175-179. [pmid: 11957166].
Leon AR, Greenberg JM, Kanuru N, Baker CM, Mera FV, Smith AL, Langberg JJ, DeLurgio DB. Cardiac resynchronization in patients with congestive heart failure and chronic atrial fibrillation: effect of upgrading to biventricular pacing after chronic right ventricular pacing. J Am Coll Cardiol. 2002:1258-1263. [pmid: 11955841].
Pires R, Elvas L, Monteiro P, Cristovao J, Antunes A, Ventura M, Costa M, Ermida P, Providencia LA. Biventricular pacing--early experience. Rev Port Cardiol. 2001:1235-1239. [pmid: 11865683].
Lunati M, Paolucci M, Oliva F, Frigerio M, Magenta G, Cattafi G, Vecchi R, Vicini I, Cavaglia S. Patient selection for biventricular pacing. J Cardiovasc Electrophysiol. 2002:S63-S67. [pmid: 11843470].
Yu CM, Chau E, Sanderson JE, Fan K, Tang MO, Fung WH, Lin H, Kong SL, Lam YM, Hill MR, Lau CP. Tissue Doppler echocardiographic evidence of reverse remodeling and improved synchronicity by simultaneously delaying regional contraction after biventricular pacing therapy in heart failure. Circulation. 2002:438-445. [pmid: 11815425].
Oguz E, Dagdeviren B, Bilsel T, Akdemir O, Erdinler I, Akyol A, Ulufer T, Tezel T, Gurkan K. Echocardiographic prediction of long-term response to biventricular pacemaker in severe heart failure. Eur J Heart Fail. 2002:83-90. [pmid: 11812668].
Reuter S, Garrigue S, Barold SS, Jais P, Hocini M, Haissaguerre M, Clementy J. Comparison of characteristics in responders versus nonresponders with biventricular pacing for drug-resistant congestive heart failure. Am J Cardiol. 2002:346-350. [pmid: 11809441].
Garrigue S, Reuter S, Labeque JN, Jais P, Hocini M, Shah DC, Haissaguerre M, Clementy J. Usefulness of biventricular pacing in patients with congestive heart failure and right bundle branch block. Am J Cardiol. 2001:1436-1441. A8. [pmid: 11741571].
Stellbrink C, Breithardt OA, Franke A, Sack S, Bakker P, Auricchio A, Pochet T, Salo R, Kramer A, Spinelli J. Impact of cardiac resynchronization therapy using hemodynamically optimized pacing on left ventricular remodeling in patients with congestive heart failure and ventricular conduction disturbances. J Am Coll Cardiol. 2001:1957-1965. [pmid: 11738300].
Zagrodzky JD, Ramaswamy K, Page RL, Joglar JA, Sheehan CJ, Smith ML, Hamdan MH. Biventricular pacing decreases the inducibility of ventricular tachycardia in patients with ischemic cardiomyopathy. Am J Cardiol. 2001:1208-1210. A7. [pmid: 11356402].
Kim WY, Sogaard P, Mortensen PT, Jensen HK, Pedersen AK, Kristensen BO, Egeblad H. Three dimensional echocardiography documents haemodynamic improvement by biventricular pacing in patients with severe heart failure. Heart. 2001:514-520. [pmid: 11303000].
Lau CP, Yu CM, Chau E, Fan K, Tse HF, Lee K, Tang MO, Wan SH, Law TC, Lee PY, Lam YM, Hill MR. Reversal of left ventricular remodeling by synchronous biventricular pacing in heart failure. Pacing Clin Electrophysiol. 2000:1722-1725. [pmid: 11139909].
Braunschweig F, Linde C, Gadler F, Ryden L. Reduction of hospital days by biventricular pacing. Eur J Heart Fail. 2000:399-406. [pmid: 11113717].
Hamdan MH, Zagrodzky JD, Joglar JA, Sheehan CJ, Ramaswamy K, Erdner JF, Page RL, Smith ML. Biventricular pacing decreases sympathetic activity compared with right ventricular pacing in patients with depressed ejection fraction. Circulation. 2000:1027-1032. [pmid: 10961968].
Bakker PF, Meijburg HW, de Vries JW, Mower MM, Thomas AC, Hull ML, Robles De Medina EO, Bredee JJ. Biventricular pacing in end-stage heart failure improves functional capacity and left ventricular function. J Interv Card Electrophysiol. 2000:395-404. [pmid: 10936005].
Farwell D, Patel NR, Hall A, Ralph S, Sulke AN. How many people with heart failure are appropriate for biventricular resynchronization?. Eur Heart J. 2000:1246-1250. [pmid: 10924314].
Kerwin WF, Botvinick EH, O'Connell JW, Merrick SH, DeMarco T, Chatterjee K, Scheibly K, Saxon LA. Ventricular contraction abnormalities in dilated cardiomyopathy: effect of biventricular pacing to correct interventricular dyssynchrony. J Am Coll Cardiol. 2000:1221-1227. [pmid: 10758964].
Alonso C, Leclercq C, Victor F, Mansour H, de Place C, Pavin D, Carre F, Mabo P, Daubert JC. Electrocardiographic predictive factors of long-term clinical improvement with multisite biventricular pacing in advanced heart failure. Am J Cardiol. 99:1417-1421.
Stellbrink C, Auricchio A, Diem B, Breithardt OA, Kloss M, Schondube FA, Klein H, Messmer BJ, Hanrath P. Potential benefit of biventricular pacing in patients with congestive heart failure and ventricular tachyarrhythmia. Am J Cardiol. 99:143D-150D.
Saxon LA, Kerwin WF, Cahalan MK, Kalman JM, Olgin JE, Foster E, Schiller NB, Shinbane JS, Lesh MD, Merrick SH. Acute effects of intraoperative multisite ventricular pacing on left ventricular function and activation/contraction sequence in patients with depressed ventricular function. J Cardiovasc Electrophysiol. 98:13-21.
Auricchio A, Salo RW. Acute hemodynamic improvement by pacing in patients with severe congestive heart failure. Pacing Clin Electrophysiol. 97:313-324.
Cazeau S, Ritter P, Lazarus A, Gras D, Backdach H, Mundler O, Mugica J. Multisite pacing for end-stage heart failure: early experience. Pacing Clin Electrophysiol. 96:1748-1757.
Nishimura RA, Hayes DL, Holmes DR Jr, Tajik AJ. Mechanism of hemodynamic improvement by dual-chamber pacing for severe left ventricular dysfunction: an acute Doppler and catheterization hemodynamic study. J Am Coll Cardiol. 95:281-288.
Stanton T, Haluska BA, Leano R, Marwick TH. Hemodynamic benefit of rest and exercise optimization of cardiac resynchronization therapy. Echocardiography. 2014.
Vassilikos VP, Mantziari L, Dakos G, Kamperidis V, Chouvarda I, Chatzizisis YS, Kalpidis P, Theofilogiannakos E, Paraskevaidis S, Karvounis H, Mochlas S, Maglaveras N, Styliadis IH. QRS analysis using wavelet transformation for the prediction of response to cardiac resynchronization therapy: A prospective pilot study. J. Electrocardiol. 2014:59-65. [pmid: 24034302].
Lee Y, Mori N, Nakamura D, Yoshimura T, Taniike M, Makino N, Kato H, Egami Y, Shutta R, Tanouchi J, Yamada Y, Nishino M. New Approach for Rotational Dyssynchrony Using Three-Dimensional Speckle Tracking Echocardiography. Echocardiography. 2013.
Ellims AH, Pfluger H, Elsik M, Butler MJ, Hare JL, Taylor AJ. Utility of cardiac magnetic resonance imaging, echocardiography and electrocardiography for the prediction of clinical response and long-term survival following cardiac resynchronisation therapy. Int. J. Card. Imaging. 2013:1303-1311.
Thibault B, Dubuc M, Khairy P, Guerra PG, MacLe L, Rivard L, Roy D, Talajic M, Karst E, Ryu K, Paiement P, Farazi TG. Acute haemodynamic comparison of multisite and biventricular pacing with a quadripolar left ventricular lead. Europace. 2013:984-991. [pmid: 23447571].
Doltra A, Bijnens B, Tolosana JM, Gabrielli L, Castel MA, Berruezo A, Brugada J, Mont L, Sitges M. Effect of cardiac resynchronization therapy on left ventricular diastolic function: Implications for clinical outcome. J. Card. Fail. 2013:795-801. [pmid: 24216100].
Uebleis C, Hellweger S, Laubender RP, Becker A, Sohn H-Y, Lehner S, Haug A, Bartenstein P, Cumming P, Van Kriekinge SD, Slomka PJ, Hacker M. Left ventricular dyssynchrony assessed by gated SPECT phase analysis is an independent predictor of death in patients with advanced coronary artery disease and reduced left ventricular function not undergoing cardiac resynchronization therapy. Eur. J. Nucl. Med. Mol. Imaging. 2012:1561-1569. [pmid: 22752450].
Fouad DA, Eldeen RMS. The role of real time three dimensional echocardiography to guide optimal lead positioning and improve response to cardiac resynchronization therapy: A prospective pilot study. Egypt. Heart J. 2012:155-163.
O'Connor K, Senechal M, Lancellotti P, Dubois M, Magne J, Champagne J, Philippon F, Pierard L, O'Hara G. Usefulness of cardiac resynchronisation therapy in patients with right bundle branch block: Is viability an important piece of the puzzle?. Int. J. Cardiol. 2010:e17-e20. [pmid: 19168245].
Reinsch N, Konorza T, Woydowski D, Bruck H, Volsek M, Muller-Tasch T, Neumann T, Erbel R, Wieneke H. Iterative cardiac output measurement for optimizing cardiac resynchronization therapy: A randomized, blinded, crossover study. PACE Pacing Clin. Electrophysiol. 2010:1188-1194. [pmid: 20663072].
Miyazaki C, Redfield MM, Powell BD, Lin GM, Herges RM, Hodge DO, Olson LJ, Hayes DL, Espinosa RE, Rea RF, Bruce CJ, Nelson SM, Miller FA, Oh JK. Original articles dyssynchrony indices to predict response to cardiac resynchronization therapy a comprehensive prospective single-center study. Circ. Heart Fail. 2010:565-573. [pmid: 20647479].
Smolis-Bak E, Chwyczko T, Wojcicka M, Kowalik I, Kazimierska B, Dabrowski R, Sterlinski M, Maciag A, Szwed H. Evaluation of exercise tolerance and quality of life and their correlation in patients treated with cardiac resynchronization therapy (CRT): Ocena wydolnosci fizycznej i jakosci zycia oraz zaleznosci wystepujacych pomiedzy badanymi parametrami u pacjentow leczonych stymulacja resynchronizujaca (CRT). Fizjoterapia. 2009:3-9.
Cattadori G, Giraldi F, Berti M, Carbucicchio C, Pepi M, Della Bella P, Contini M, Apostolo A, Berna G, Andreini D, Sciomer S, Agostoni P. Assessment of cardiac resynchronization therapy response. Int. J. Cardiol. 2009:240-242. [pmid: 18672300].
Saeid AK, Bozorgi A, Davoodi G, Sadeghian S, Yaminisharif A, Moezi A, Alenabi T, Khoshnevis M. Comparison of benefits from cardiac resynchronization therapy between patients with ischemic cardiomyopathy and patients with idiopathic dilated cardiomyopathy. J. Tehran. Uni. Heart. Cent. 2009:115-118.
De Roest G, Knaapen P, Gotte M, Hendriks T, Allaart C, De Cock C, Van Rossum A. Stroke work or systolic dP/dtmax to evaluate acute response to cardiac resynchronization therapy: are they interchangeable?. Eur. J. Heart Fail. 2009:706-708. [pmid: 19553399].
Olsen NT, Mogelvang R, Jons C, Fritz-Hansen T, Sogaard P. Predicting Response to Cardiac Resynchronization Therapy with Cross-Correlation Analysis of Myocardial Systolic Acceleration: A New Approach to Echocardiographic Dyssynchrony Evaluation. J. Am. Soc. Echocardiogr. 2009:657-664. [pmid: 19423287].
Edner M, Kim Y, Hansen KN, Nissen H, Espersen G, La Rosee K, Maru F, Freemantle N, Cleland J, Sogaard P. Prevalence and inter-relationship of different Doppler measures of dyssynchrony in patients with heart failure and prolonged QRS: A report from CARE-HF. Cardiovasc. Ultrasound. 2009.
Tolosana JM, Hernandez Madrid A, Brugada J, Sitges M, Garcia Bolao I, Fernandez Lozano I, Martinez Ferrer J, Quesada A, Macias A, Marin W, Escudier JM, Gomez AA, Gimenez Alcala M, Tamborero D, Berruezo A, Mont L. Comparison of Benefits and Mortality in Cardiac Resynchronization Therapy in Patients With Atrial Fibrillation Versus Patients in Sinus Rhythm (Results of the Spanish Atrial Fibrillation and Resynchronization [SPARE] Study). Am. J. Cardiol. 2008:444-449. [pmid: 18678303].
Phillips KP, Harberts DB, Johnston LP, O'Donnell D. Left ventricular resynchronization predicted by individual performance of right and left univentricular pacing: A study on the impact of sequential biventricular pacing on ventricular dyssynchrony. Heart Rhythm. 2007:147-153. [pmid: 17275748].
Santos JF, Parreira L, Madeira J, Seixo F, Mendes L, Lopes C, Venancio J, Lourenco J, Caetano F, Ines L, Mendes M. Predictors of response to cardiac resynchronization therapy - Importance of left ventricular dyssynchrony: Preditores de resposta a terapeutica de ressincronizac ao cardiaca - Importancia da dessincronia ventricular esquerda. Rev. Port. Cardiol. 2006:569-581. [pmid: 17019976].
Ellery S, Pakrashi T, Paul V, Sack S. Predicting mortality and rehospitalization in heart failure patients with Home Monitoring - The Home CARE pilot study. Clin. Res. Cardiol. 2006:III/29-III/35.
Hernandez Madrid A, Escobar Cervantes C, Marin Marin I, Bernal Morell E. Cardiac resynchronization. Socioeconomic and health care impact. Mortality of procedure. Cost-benefit ratio. Impact on functional class/quality of life. Prognosis and follow-up: Resincronizacion cardiaca. Impacto socioeconomico sanitario. Mortalidad del procedimiento. Relacion coste-beneficio. Impacto en la clase funcional/calidad de vida. Pronostico y seguimiento. Invest. Cardiovasc. 2005:135-150.
Cowburn PJ, Patel H, Jolliffe RE, Wald RW, Parker JD. Cardiac resynchronisation therapy: An option for inotrope-supported patients with end-stage heart failure?. Eur. J. Heart Fail. 2005:215-217. [pmid: 15701469].
Knuuti J, Sundell J, Naum A, Engblom E, Koistinen J, Ylitalo A, Stolen KQ, Kalliokoski R, Nekolla SG, Bax KEJJ, Airaksinen KEJ. Assessment of right ventricular oxidative metabolism by PET in patients with idiopathic dilated cardiomyopathy undergoing cardiac resynchronisation therapy. Eur. J. Nucl. Med. Mol. Imaging. 2004:1592-1598. [pmid: 15290120].
Ferreira Santos J, Caetano F, Parreira L, Madeira J, Cardoso P, Fonseca N, Segurado F, Neves Soares L, Ines L. Tissue Doppler Echocardiography for Evaluation of Patients with Ventricular Resynchronization Therapy: Ecocardiografia com Doppler Tecidular para Avaliacao de Doentes com Terapeutica de Ressincronizacao Ventricular. Rev. Port. Cardiol. 2003:1363-1371. [pmid: 14768491].
Ferreira Santos J, Caetano F, Parreira L, Madeira J, Cardoso P, Fonseca N, Segurado F, Neves Soares L, Ines L. Effects of Cardiac Resynchronization Therapy on Right Ventricular Function - Evaluation with Tissue Doppler Echocardiography: Efeitos da Terapeutica de Ressincronizacao Ventricular na Funcao Ventricular Direita - Avaliacao por Ecocardiografia com Doppler Tecidular. Rev. Port. Cardiol. 2003:1347-1355. [pmid: 14768490].
Kato H, Shimano M, Sumi T, Murakami H, Kada K, Inden Y, Tsuboi N, Murohara T. Acute Improvement of Left Ventricular Relaxation as a Predictor of Volume Reduction after Cardiac Resynchronization Therapy: A Pilot Study Assessing the Value of Left Ventricular Hemodynamic Parameter. PACE Pacing Clin. Electrophysiol. 2014.
Jackson T, Sohal M, Chen Z, Child N, Sammut E, Behar J, Claridge S, Carr-White G, Razavi R, Rinaldi CA. A U-shaped type II contraction pattern in patients with strict left bundle branch block predicts super-response to cardiac resynchronization therapy. Heart Rhythm. 2014.
Paoletti Perini A, Bartolini S, Pieragnoli P, Ricciardi G, Perrotta L, Valleggi A, Vergaro G, Michelotti F, Boggian G, Sassone B, Mascioli G, Emdin M, Padeletti L. CHADS2 and CHA2DS2-VASc scores to predict morbidity and mortality in heart failure patients candidates to cardiac resynchronization therapy. Europace. 2014:71-80. [pmid: 23828875].
Kuperstein R, Goldenberg I, Moss AJ, Solomon S, Bourgoun M, Shah A, McNitt S, Zareba W, Klempfner R. Left atrial volume and the benefit of cardiac resynchronization therapy in the MADIT-CRT Trial. Circ. Heart Fail. 2014:154-160. [pmid: 24347664].
Marechaux S, Guiot A, Castel AL, Guyomar Y, Semichon M, Delelis F, Heuls S, Ennezat P-V, Graux P, Tribouilloy C. Relationship between two-dimensional speckle-tracking septal strain and response to cardiac resynchronization therapy in patients with left ventricular dysfunction and left bundle branch block: A prospective pilot study. J. Am. Soc. Echocardiogr. 2014:501-511. [pmid: 24513239].
Davoodi G, Bagheri A, Yamini-Sharif A, Boroumand M, Saroukhani S, Sahebjam M. Evaluation of in-hospital NT-proBNP changes in heart failure patients to identify the six-month clinical response following cardiac resynchronization therapy. Acta Med. Iran. 2014:15-23. [pmid: 24658981].
Kazemisaeid A, Sardari A, Ejmalian G, Lotfi-Tokaldany M, Sahebjam M, Safir-Mardanloo A, Yaminisharif A, Montazeri M, Jalali A, Sadeghian H. Predictors of response to cardiac resynchronization therapy in heart failure patients. Exp. Clin. Cardiol. 2014:3982-3990.
Zhang H, Dai Z, Xiao P, Pan C, Zhang J, Hu Z, Chen S. The left ventricular lead electrical delay predicts response to cardiac resynchronisation therapy. Heart Lung Circul. 2014:936-942.
Guha K, Konstantinou D, Mantziari L, Modi BN, Chandrasekaran B, Khalique Z, McDonagh T, Sharma R. The impact of age on clinical outcomes following cardiac resynchronisation therapy. J. Intervent. Card. Electrophysiol. 2014:95-102.
Ito T, Kizawa S, Nogi S, Shimamoto S, Yokoyama K, Ishizaka N. Association between presystolic ventricular flash and left ventricular functional recovery after cardiac resynchronization therapy. Echocardiography. 2014:149-154. [pmid: 23906029].
Wang JY, Zhang P, Li XB, Zhu TG, Li H, Wang L, Li D, Wu CC, Gao Y, Tian Y, Guo JH. Presence of notched QRS on paced electrocardiographs as a predictor of poor response to cardiac resynchronization therapy. Chin. Med. J. 2014:2727-2734. [pmid: 25146604].
Chatterjee NA, Upadhyay GA, Singal G, Parks KA, Dec GW, Singh JP, Lewis GD. Pre-capillary pulmonary hypertension and right ventricular dilation predict clinical outcome in cardiac resynchronization therapy. JACC Heart Fail. 2014:230-237. [pmid: 24952689].
Stankovic I, Aarones M, Smith H-J, Voros G, Kongsgaard E, Neskovic AN, Willems R, Aakhus S, Voigt J.-U. Dynamic relationship of left-ventricular dyssynchrony and contractile reserve in patients undergoing cardiac resynchronization therapy. Eur. Heart. J. 2014:48-55a. [pmid: 23918757].
Vassilikos VP, Mantziari L, Dakos G, Kamperidis V, Chouvarda I, Chatzizisis YS, Kalpidis P, Theofilogiannakos E, Paraskevaidis S, Karvounis H, Mochlas S, Maglaveras N, Styliadis IH. QRS analysis using wavelet transformation for the prediction of response to cardiac resynchronization therapy: A prospective pilot study. J. Electrocardiol. 2014:59-65. [pmid: 24034302].
Lalonde M, Wells RG, Birnie D, Ruddy TD, Wassenaar R. Development and optimization of SPECT gated blood pool cluster analysis for the prediction of CRT outcome. Med. Phys. 2014.
Ruan Z-B, Zhu L, Chen G-C, Yin Y-G. Predictive value of serum cystatin C on cardiac resynchronization therapy. Exp. Clin. Cardiol. 2014:3434-3446.
Lenarczyk R, Jedrzejczyk-Patej E, Mazurek M, Szulik M, Kowalski O, Pruszkowska P, Sokal A, Sredniawa B, Boidol J, Kowalczyk J, Podolecki T, Mencel G, Kalarus Z. Quality of Life in Cardiac Resynchronization Recipients: Association with Response and Impact on Outcome. Pacing Clin Electrophysiol. 2014.
Mascioli G, Lombardi C, Franceschini F, Metra M, Lucca E, Michelotti F, Canevese F, Bakhtadze N, Belvito C, Sciatti E, Vizzardi E, Bontempi L, Curnis A. Effects of immune system on long-term results of cardiac resynchronization therapy. Minerva Cardioangiol. 2014.
Varma N. Left ventricular electrical activation during right ventricular pacing in heart failure patients with LBBB: Visualization by electrocardiographic imaging and implications for cardiac resynchronization therapy. J Electrocardiol. 2014.
Bilchick KC, Stukenborg GJ. Comparative Effectiveness of Cardiac Resynchronization Therapy in Combination With Implantable Defibrillator in Patients With Heart Failure and Wide QRS Duration. Am J Cardiol. 2014.
Engels EB, Vegh EM, VAN Deursen CJ, Vernooy K, Singh JP, Prinzen FW. T-Wave Area Predicts Response to Cardiac Resynchronization Therapy in Patients with Left Bundle Branch Block. J Cardiovasc Electrophysiol. 2014.
Cipriani M, Landolina M, Oliva F, Ghio S, Vargiu S, Rordorf R, Raineri C, Ammirati E, Petracci B, Campo C, Bisetti S, Lunati M. Women with nonischemic cardiomyopathy have a favorable prognosis and a better left ventricular remodeling than men after cardiac resynchronization therapy. J Cardiovasc Med (Hagerstown). 2014.
Agacdiken Agir A, Celikyurt U, Sahin T, Yilmaz I, Karauzum K, Bozyel S, Ural D, Vural A. What is the lowest value of left ventricular baseline ejection fraction that predicts response to cardiac resynchronization therapy?. Med Sci Monit. 2014:1641-1646. [pmid: 25218410].
Schmitz B, DeMaria R, Gatsios D, Chrysanthakopoulou T, Landolina M, Gasparini M, Campolo J, Parolini M, Sanzo A, Galimberti P, Bianchi M, Lenders M, Brand E, Parodi O, Lunati M, Brand SM. Identification of Genetic Markers for Treatment Success in Heart Failure Patients: Insight from Cardiac Resynchronization Therapy. Circ Cardiovasc Genet. 2014.
Schuchert A, Muto C, Maounis T, Ella RO, Polauck A, Padeletti L. Relationship between pre-implant ejection fraction and outcome after cardiac resynchronization therapy in symptomatic patients. Acta Cardiol. 2014:424-432. [pmid: 25181918].
Ziaeian B, Zhang Y, Albert NM, Curtis AB, Gheorghiade M, Heywood JT, Mehra MR, O'Connor CM, Reynolds D, Walsh MN, Yancy CW, Fonarow GC. Clinical effectiveness of CRT and ICD therapy in heart failure patients by racial/ethnic classification: insights from the IMPROVE HF registry. J Am Coll Cardiol. 2014:797-807. [pmid: 25145524].
Gage RM, Burns KV, Bank AJ. Echocardiographic and clinical response to cardiac resynchronization therapy in heart failure patients with and without previous right ventricular pacing. Eur J Heart Fail. 2014.
Ruwald AC, Kutyifa V, Ruwald MH, Solomon S, Daubert JP, Jons C, Brenyo A, McNitt S, Do D, Tanabe K, Al-Ahmad A, Wang P, Moss AJ, Zareba W. The association between biventricular pacing and cardiac resynchronization therapy-defibrillator efficacy when compared with implantable cardioverter defibrillator on outcomes and reverse remodelling. Eur Heart J. 2014.
Friedman DJ, Upadhyay GA, Rajabali A, Altman RK, Orencole M, Parks KA, Moore SA, Park MY, Picard MH, Ruskin JN, Singh JP, Heist EK. Progressive ventricular dysfunction among nonresponders to cardiac resynchronization therapy: Baseline predictors and associated clinical outcomes. Heart Rhythm. 2014.
Sohal M, Duckett SG, Zhuang X, Shi W, Ginks M, Shetty A, Sammut E, Kozerke S, Niederer S, Smith N, Ourselin S, Rinaldi C, Rueckert D, Carr-White G, Razavi R. A prospective evaluation of cardiovascular magnetic resonance measures of dyssynchrony in the prediction of response to cardiac resynchronization therapy. J Cardiovasc Magn Reson. 2014:58. [pmid: 25084814].
Djordjevic Dikic A, Nikcevic G, Raspopovic S, Jovanovic V, Tesic M, Beleslin B, Stepanovic J, Giga V, Milasinovic G. Prognostic role of coronary flow reserve for left ventricular functional improvement after cardiac resynchronization therapy in patients with dilated cardiomyopathy. Eur Heart J Cardiovasc Imaging. 2014.
Yang XW, Hua W, Wang J, Liu ZM, Ding LG, Chen KP, Zhang S. Regression of Fragmented QRS Complex: A Marker of Electrical Reverse Remodeling in Cardiac Resynchronization Therapy. Ann Noninvasive Electrocardiol. 2014.
Celikyurt U, Karauzum K, Sahin T, Agacdiken A, Vural A, Ural D. Association between Resolution of Fragmented QRS and Response to Cardiac Resynchronization Therapy. Ann Noninvasive Electrocardiol. 2014.
Truong QA, Januzzi JL, Szymonifka J, Thai WE, Wai B, Lavender Z, Sharma U, Sandoval RM, Grunau ZS, Basnet S, Babatunde A, Ajijola OA, Min JK, Singh JP. Coronary sinus biomarker sampling compared to peripheral venous blood for predicting outcomes in patients with severe heart failure undergoing cardiac resynchronization therapy: The BIOCRT study. Heart Rhythm. 2014.
Mitrani RD, Sager SJ, Moscucci M, Cogan J, Myerburg RJ. Transient variations of transthoracic impedance as a predictor of heart failure and death in patients with implanted defibrillators. Int J Cardiol. 2014:473-477. [pmid: 25012496].
Gierula J, Cubbon RM, Jamil HA, Byrom RJ, Waldron ZL, Pavitt S, Kearney MT, Witte KK. Patients with long-term permanent pacemakers have a high prevalence of left ventricular dysfunction. J Cardiovasc Med (Hagerstown). 2014.
Kutyifa V, Stockburger M, Daubert JP, Holmqvist F, Olshansky B, Schuger C, Klein H, Goldenberg I, Brenyo A, McNitt S, Merkely B, Zareba W, Moss AJ. PR interval identifies clinical response in patients with non-left bundle branch block: a Multicenter Automatic Defibrillator Implantation Trial-Cardiac Resynchronization Therapy substudy. Circ Arrhythm Electrophysiol. 2014:645-651. [pmid: 24963007].
Bose A, Upadhyay GA, Kandala J, Heist EK, Mela T, Parks KA, Singh JP. Does Prior Valve Surgery Change Outcome in Patients Treated with Cardiac Resynchronization Therapy?. J Cardiovasc Electrophysiol. 2014.
Derval N, Bordachar P, Lim HS, Sacher F, Ploux S, Laborderie J, Steendijk P, Deplagne A, Ritter P, Garrigue S, Denis A, Hocini M, Haissaguerre M, Clementy J, Jais P. Impact of Pacing Site on QRS Duration and Its Relationship to Hemodynamic Response in Cardiac Resynchronization Therapy for Congestive Heart Failure. J Cardiovasc Electrophysiol. 2014:1012-1020. [pmid: 24891271].
Bogdan S, Klempfner R, Sabbag A, Luria D, Gurevitz O, Bar-Lev D, Lipchenca I, Nof E, Kuperstein R, Goldenberg I, Eldar M, Glikson M, Beinart R. Functional Response to Cardiac Resynchronization Therapy in Patients with Renal Dysfunction and Subsequent Long-Term Mortality. J Cardiovasc Electrophysiol. 2014.
Khatib M, Tolosana JM, Trucco E, Borras R, Castel A, Berruezo A, Doltra A, Sitges M, Arbelo E, Matas M, Brugada J, Mont L. EAARN score, a predictive score for mortality in patients receiving cardiac resynchronization therapy based on pre-implantation risk factors. Eur J Heart Fail. 2014:802-809. [pmid: 24863467].
Sharma AK, Vegh EM, Kandala J, Orencole M, Januszkiewicz L, Bose A, Miller A, Parks KA, Heist EK, Singh JP. Usefulness of hyponatremia as a predictor for adverse events in patients with heart failure receiving cardiac resynchronization therapy. Am J Cardiol. 2014:83-87. [pmid: 24852916].
Rinkuniene D, Bucyte S, Ceseviciute K, Abramavicius S, Baronaite-Dudoniene K, Laukaitiene J, Kazakevicius T, Zabiela V, Sileikis V, Puodziukynas A, Jurkevicius R. Predictors of positive response to cardiac resynchronization therapy. BMC Cardiovasc Disord. 2014:55. [pmid: 24779476].
Eisen A, Suleiman M, Strasberg B, Sela R, Rosenheck S, Freedberg NA, Geist M, Ben-Zvi S, Goldenberg I, Glikson M, Haim M. Renal Dysfunction and Clinical Outcomes of Patients Undergoing ICD and CRTD Implantation: Data from the Israeli ICD Registry. J Cardiovasc Electrophysiol. 2014:990-997. [pmid: 24761993].
Looi KL, Gajendragadkar PR, Khan FZ, Elsik M, Begley DA, Fynn SP, Grace AA, Heck PM, Virdee M, Agarwal S. Cardiac resynchronisation therapy: pacemaker versus internal cardioverter-defibrillator in patients with impaired left ventricular function. Heart. 2014:794-799. [pmid: 24691411].
Adelstein E, Schwartzman D, Bazaz R, Jain S, Gorcsan J 3rd, Saba S. Outcomes in pacemaker-dependent patients upgraded from conventional pacemakers to cardiac resynchronization therapy-defibrillators. Heart Rhythm. 2014:1008-1014. [pmid: 24657426].
Bilchick KC, Kuruvilla S, Hamirani YS, Ramachandran R, Clarke SA, Parker KM, Stukenborg GJ, Mason P, Ferguson JD, Moorman JR, Malhotra R, Mangrum JM, Darby AE, Dimarco J, Holmes JW, Salerno M, Kramer CM, Epstein FH. Impact of mechanical activation, scar, and electrical timing on cardiac resynchronization therapy response and clinical outcomes. J Am Coll Cardiol. 2014:1657-1666. [pmid: 24583155].
Gabrielli L, Marincheva G, Bijnens B, Doltra A, Tolosana JM, Borras R, Castel MA, Berruezo A, Brugada J, Mont L, Sitges M. Septal flash predicts cardiac resynchronization therapy response in patients with permanent atrial fibrillation. Europace. 2014:1342-1349. [pmid: 24576973].
Ogano M, Iwasaki YK, Tanabe J, Takagi H, Umemoto T, Hayashi M, Miyauchi Y, Shimizu W. Cardiac resynchronization therapy restored ventricular septal myocardial perfusion and enhanced ventricular remodeling in patients with nonischemic cardiomyopathy presenting with left bundle branch block. Heart Rhythm. 2014:836-841. [pmid: 24561161].
Sardu C, Marfella R, Santulli G. Impact of diabetes mellitus on the clinical response to cardiac resynchronization therapy in elderly people. J Cardiovasc Transl Res. 2014:362-368. [pmid: 24500410].
D'Onofrio A, Botto G, Mantica M, LA Rosa C, Occhetta E, Verlato R, Molon G, Ammendola E, Villani GQ, Bongiorni MG, Bianchi V, Gelmini GP, Valsecchi S, Ciardiello C. Incremental value of larger interventricular conduction time in improving cardiac resynchronization therapy outcome in patients with different QRS duration. J Cardiovasc Electrophysiol. 2014:500-506. [pmid: 24494797].
Poller WC, Dreger H, Schwerg M, Bondke H, Melzer C. Not left ventricular lead position, but the extent of immediate asynchrony reduction predicts long-term response to cardiac resynchronization therapy. Clin Res Cardiol. 2014:457-466. [pmid: 24468897].
Auger D, Hoke U, Thijssen J, Abate E, Yiu KH, Ewe SH, Witkowski TG, Leong DP, Holman ER, Ajmone Marsan N, Schalij MJ, Bax JJ, Delgado V. Effect of cardiac resynchronization therapy on the sequence of mechanical activation assessed by two-dimensional radial strain imaging. Am J Cardiol. 2014:982-987. [pmid: 24462070].
Antonio N, Soares A, Carvalheiro T, Fernandes R, Paiva A, Ventura M, Cristovao J, Elvas L, Goncalves L, Providencia LA, Ribeiro CF, Pego GM. Circulating endothelial progenitor cells as a predictor of response to cardiac resynchronization therapy: the missing piece of the puzzle?. Pacing Clin Electrophysiol. 2014:731-739. [pmid: 24383551].
Ruwald AC, Pietrasik G, Goldenberg I, Kutyifa V, Daubert JP, Ruwald MH, Jons C, McNitt S, Wang P, Zareba W, Moss AJ. The effect of intermittent atrial tachyarrhythmia on heart failure or death in cardiac resynchronization therapy with defibrillator versus implantable cardioverter-defibrillator patients: a MADIT-CRT substudy (Multicenter Automatic Defibrillator Implantation Trial With Cardiac Resynchronization Therapy). J Am Coll Cardiol. 2014:1190-1197. [pmid: 24333490].
Kydd AC, Khan F, Gopalan D, Ring L, Rana BS, Virdee MS, Dutka DP. Utility of speckle tracking echocardiography to characterize dysfunctional myocardium in patients with ischemic cardiomyopathy referred for cardiac resynchronization therapy. Echocardiography. 2014:736-743. [pmid: 24303794].
Zecchin M, Proclemer A, Magnani S, Vitali-Serdoz L, Facchin D, Muser D, Nordio A, Barbati G, Puggia I, Sinagra G, Proclemer A. Long-term outcome of 'super-responder' patients to cardiac resynchronization therapy. Europace. 2014:363-371. [pmid: 24189477].
Marek JJ, Saba S, Onishi T, Ryo K, Schwartzman D, Adelstein EC, Gorcsan IIIJ. Usefulness of echocardiographically guided left ventricular lead placement for cardiac resynchronization therapy in patients with intermediate QRS width and non-left bundle branch block morphology. American journal of cardiology. 2014:107-116. [pmid: 24169014].