# Forms

Figure B1 Abstract Review Form

Figure B1 Title/abstract screen: This image is a screen shot of the title/abstract screen form used by the systematic review team to screen articles for applicability and categorization.

Figure B2 Article Review Form

Figure B2 Article screen: This image is a screen shot of the article screen form used by the systematic review team to screen articles for applicability and categorization.

## Data Abstraction Form

Table B1 Study characteristics

- Author, Year, RefID; - Does this study have a name? If YES please specifty; - Is this a secondary study of a large clinical trial? -If YES please specify; - Planned length of follow-up -specify (months); - Study Design; - Other Study design-Specify; - Device type; - Device Name; - Other Device Name; - Funding source; - Other Funding-Specify

Table B2 Participants characteristics

- Author, Year, Refid; - Arm; - Arm name; - Number at baseline; - Women, n; - Women, (%); - Mean Age, years; - Median Age, years; - Range Age, years; - SD Age, years; - White, n; - White,(%); - African-American, n; - African-American, (%); - Other, n,; - Other,(%); - Ischemic cardiomypathy n; - Ischemic cardiomypathy (%); - Atrial fibrillation, n; - Atrial fibrillation, (%); - QRS interval, mean; QRS interval, median; QRS interval, range; QRS interval, SD; - Creatinnie ; Creatinnie-unit; - LBBB, n; LBBB,%; - RBBB, n; RBBB,(%); - QRS morphology -IVCD, n; QRS morphology -IVCD, %; - QRS morphology -PBBBlock, n; QRS morphology -PBBBlock,%; - NYHA class I, n; NYHA class I, (%); - NYHA class II, n; NYHA class II, (%); - NYHA class III, n; NYHA class III, (%); - NYHA class IV, n; NYHA class IV, (%); - LVEF, mean; LVEF, median LVEF, range; - GFR (Glomerular filtration rate); GFR -Please enter UNIT; - Other - please specify

Table B3 Effectiveness outcomes

The following apply to the outcomes of, 6 minute hall walk distance, Minnesota living with Heart failure Inventory score (MLHFI), SF-36, LVESV/volume index, LVEDV/volume index, LVEF, Clinical composite score.

- Author, year, RefID; - Arm name; - Outcome unit -if applicable; - Baseline N; - Baseline outcome, mean; - Baseline outcome, SD; - Timepoint(s); - N at time point(s); - mean-Outcome at timepoint(s); - SD-Outcome at timepoint(s); - Within arm comparison-Select Measurement; - Within arm comparison-Enter Value Relative risk; - Relative hazard; - Odd ratio; - risk difference; - 95% CI; - Standard error; - Standard deviation; - p value; - Between arm comparison - Select Measurement; - Between arm comparison - Enter Valuse; - Comparator Arm; - Relative risk; - Relative hazard; - Odd ratio; - risk difference; - 95% CI; - Standard error; - Standard deviation; - p value

Table B4 Hospitalization for heart failure and All-cause mortality outcome

- Author, year, RefID; - Arm name; - N for analysis; - Time point; - n of PATIENTS with outcomes; - % of PATIENTS with outcomes; - n of EVENTS with outcomes; - % of EVENTS with outcomes; - Within arm comparison-Select Measurement; - Within arm comparison-Enter Value Relative risk; - Relative hazard; - Odd ratio; - risk difference; - 95% CI; - Standard error; - Standard deviation; - p value; - Between arm comparison - Select Measurement; - Between arm comparison - Enter Valuse; - Comparator Arm; - Relative risk; - Relative hazard; - Odd ratio; - risk difference; - 95% CI; - Standard error; - Standard deviation; - p value

Table B5 Harms Outcomes

- Author, year, RefID; - Overall Study-If applicable; - Arm name; - Select Outcome; - IF Length of hospital stay -Enter Value; - IF Length of hospital stay -Select Unit; - N for analysis; - Time point (s); - n of PATIENTS with outcomes; - % of PATIENTS with outcomes; - n of EVENTS with outcomes; - % of EVENTS with outcomes; - Within arm comparison-Select Measurement; - Within arm comparison-Enter Value Relative risk; - Relative hazard; - Odd ratio; - risk difference; - 95% CI; - Standard error; - Standard deviation; - p value; - Between arm comparison - Select Measurement; - Between arm comparison - Enter Valuse; - Comparator Arm; - Relative risk; - Relative hazard; - Odd ratio; - risk difference; - 95% CI; - Standard error; - Standard deviation; - p value

Table B6 Predictors outcomes

- Author, year, RefID; - Overall study -If applicable; - Arm name Select predictor; - Define predictor -If applicable; - Enter unit- if applicable; - N for analysis; - Time point (s); - Proportion of responder, %; - Select the Model; - Other moder-specify; - Unadjusted result; - Relative risk; - Relative hazard; - Odd ratio; - risk difference; - 95% CI; - Standard error; - Standard deviation; - p value; - Fully adjusted result; - Relative risk; - Relative hazard; - Odd ratio; - risk difference; - 95% CI; - Standard error; - Standard deviation; - p value