# Detailed Electronic Database Search Strategies

## PubMed Strategy

(Heart Failure [mh] OR "heart failure" [tiab] OR "Cardiac Failure" [tiab] OR "Myocardial Failure" [tiab] OR "Heart Decompensation" [tiab]OR “Left Ventricular Dysfunction” [tiab] OR cardiomyopathy[tiab]) AND ("cardiac resynchronization therapy"[mh] OR resynchronization [tiab] OR resynchronisation [tiab] OR defibrillators [mh] OR defibrillators [tiab] OR defibrillator [tiab]OR biventricular[tiab] OR pacing[tiab] OR "pacemaker" [tiab] OR "pacemakers"[tiab] OR pacemaker[mh])AND "1995/01/01"[PDat] : "2014/12/31"[PDat] NOT (animals[mh] NOT Humans[mh]) AND English[lang] NOT (letter[pt] OR comment[pt] OR editorial[pt] OR review[pt])

## Embase Strategy

'heart failure'/exp OR 'heart failure':ab,ti OR 'cardiac failure':ab,ti OR 'myocardial failure':ab,ti OR 'heart decompensation':ab,ti OR 'left ventricular dysfunction':ab,ti OR cardiomyopathy:ab,ti AND ('cardiac resynchronization therapy'/exp OR resynchronization:ab,ti ORresynchronisation:ab,ti OR 'defibrillator'/exp OR defibrillators:ab,ti OR defibrillator:ab,ti OR biventricular:ab,ti OR pacing:ab,ti ORpacemaker:ab,ti OR pacemakers:ab,ti OR 'artificial heart pacemaker'/exp) NOT ('animal'/exp NOT 'human'/exp) AND [english]/lim AND ([article]/lim OR [article in press]/lim) AND [embase]/lim AND [1995–2014]/py

## The Cochrane Central Register of Controlled Trials (CENTRAL) Strategy

#1 MeSH descriptor: [Heart Failure] explode all trees 5598

#2 "heart failure":ti,ab,kw 10864

#3 "Cardiac Failure":ti,ab,kw 450

#4 "Myocardial Failure":ti,ab,kw 20

#5 "Heart Decompensation":ti,ab,kw 4

#6 "Left Ventricular Dysfunction":ti,ab,kw 875

#7 cardiomyopathy:ti,ab,kw 1588

#8 #1 or #2 or #3 or #4 or #5 or #6 or #7 12471

#9 MeSH descriptor: [Cardiac Resynchronization Therapy] explode all trees 170

#10 resynchronization:ti,ab,kw 515

#11 resynchronisation:ti,ab,kw 31

#12 MeSH descriptor: [Defibrillators] explode all trees 919

#13 defibrillators:ti,ab,kw 1321

#14 defibrillator:ti,ab,kw 1321

#15 biventricular:ti,ab,kw 246

#16 pacing:ti,ab,kw 2712

#17 pacemaker:ti,ab,kw 1202

#18 pacemakers:ti,ab,kw 1202

#19 MeSH descriptor: [Pacemaker, Artificial] explode all trees 629

#20 #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 4294

#21 #8 and #20 Publication Date from 1995 to 2014 963

## ClinicalTrials.gov Strategy

We reviewed ongoing trials listed in the clinicaltrials.gov website that contained either the search term “cardiac resynchronization therapy” or “CRT” or “biventricular pacing”, received from 01/22/2014 to 01/21/2015 and were conducted in those >≥18years of age