# Executive Summary

## Background

Chronic heart failure (CHF) is a major public health problem in the United States affecting an estimated 4.9 million Americans, causing high rates of hospitalization, poor quality of life, and 300,000 deaths each year.1

Cardiac resynchronization (CRT) is a pacing modality utilizing a left ventricular (LV) pacing lead with the goal of re-synchronizing myocardial contraction in patients with CHF. CRT was originally indicated in patients with significant LV dysfunction, defined as a left ventricular ejection fraction (LVEF) ≤ 35%, New York Heart Association (NYHA) class III–IV heart failure symptoms, and a QRS duration ≥120ms on optimal medical therapy.2–4 More recently, the indications for CRT expanded to include patients with minimally symptomatic heart failure (NYHA class II).5, 6 The appropriateness of CRT in patients with NYHA class I symptoms is unclear.1 The vast majority of candidates for CRT devices also have an indication for an implantable cardiac defibrillator (ICD), therefore, the large majority of patients receiving CRT in the United States receive a CRT device with a defibrillator (CRT-D) as opposed to a CRT pacemaker (CRT-P). CRT-P devices are occasionally placed in patients who wish to avoid ICD shocks or in patients with an indication for frequent ventricular pacing due to conduction disease who have an LVEF between 36–50 percent.

## Scope and Key Questions

We conducted a systematic review on the efficacy for both CRT-D and CRT-P. The questions were nominated by the Centers for Medicare and Medicaid (CMS).We sought to address the following questions for patients with an LVEF ≤35% and a QRS duration≥120ms:

- What is the effectiveness and safety of CRT-D compared to an ICD alone?
- What is the effectiveness and safety of CRT-P compared to optimal medical therapy alone?
- What is the comparative effectiveness and safety of CRT-D versus CRT-P?
- What are the clinical predictors of response in patients deemed appropriate candidates for CRT-D devices?
- What are the clinical predictors of response in patients deemed appropriate candidates for CRT-P devices?

## Methods

With input from key informants, we refined the questions, including eligibility criteria, and developed a protocol (PROSPERO registration CRD42014009981).

We searched MEDLINE, Embase®, and the Cochrane Central Register of Controlled Trials (CENTRAL) from January 1, 1995, as this is the date of first article reporting use of CRT through October 20th, 2014. We also reviewed the reference lists of all included articles, requested information from device manufacturers and searched Clinicaltrials.gov.

Citations were screened independently by two reviewers using predefined eligibility criteria. One reviewer completed data abstraction and a second reviewer checked abstraction for completeness and accuracy. Data when available by subgroups (females, QRS duration >150 ms, left bundle branch block, atrial fibrillation and non-ischemic cardiac conditions) were also abstracted. Two reviewers independently assessed risk of bias for individual studies. We used the Cochrane Collaboration’s tool for assessing the risk of bias of controlled studies.7 For nonrandomized studies, we used the Newcastle Ottawa Scale 8 and for predictor studies, we used Quality In Prognosis Studies (QUIPS) tool.9 Differences between reviewers were resolved through consensus.

All studies were summarized qualitatively. We conducted meta-analyses for an outcome when there were sufficient data (at least 3 studies of the same design) and studies were sufficiently homogenous with respect to key variables (population characteristics, intervention, and outcome measurement) using profile likelihood estimate for random effects model. We identified substantial statistical heterogeneity in the trials as an I-squared statistic with a value greater than 50 percent. All meta-analyses were conducted using STATA 12.1 (College Station, TX).

We graded the strength of evidence using the scheme recommended by the AHRQ EPC Methods Guide for Conducting Comparative Effectiveness Reviews.10 For this report, we graded the strength of evidence for the outcomes we classified during protocol development as the most important or critical outcomes, including quality of life as assessed by the Minnesota Living with Heart Failure Inventory Score (MLHFQ), left ventricular end systolic volume, hospitalizations for heart failure and, all- cause mortality.

## Results

We included 60 studies, reported in 86 articles (see Figure A).

Eight trials assessed the effectiveness of CRT-D with 7 providing data about all-cause mortality. We found moderate evidence of a benefit with CRT-D compared with ICD alone for survival in minimally symptomatic patients. There is insufficient evidence about the effect of CRT-D on all-cause mortality in patients with NYHA III–IV. CRT-D was noted to reduce heart failure hospitalizations, an effect seen primarily in patients with left bundle branch block (LBBB) morphology (6 trials; n=4736; high strength of evidence). There was also a high strength of evidence for CRT-D inducing ventricular reverse remodeling compared to ICD alone (5 trials; n=2936). A meta-analysis of three trials found a mean difference in mean change from baseline in left ventricular end systolic volume (LVESV) of −22.55 favoring CRT-D (95% CI −40.66 to −9.56). Quality of life, as measured by MLHFQ, was not different for minimally symptomatic patients (NYHA I–II) (−0.83 95% CI −9.27 to 5.30) but showed improvement with CRT-D compared to ICD alone in those with NYHA class III–IV symptoms (−10.37 95% CI −12.95 to −7.27) (high strength of evidence). CRT-D also increased six-minute hall walk distances compared to an ICD alone and improved clinical composite score. The prevalence of harms associated with CRT-D devices were as follows: cardiac perforation/tamponade (0.1–1.4%), pocket hematoma (0.9–2.8%), pneumothorax (1.3–2.8%), device infection (0.9–2.8%), and lead dislodgement (2.4% to 9.8%). No conclusions could be drawn about the association between CRT-D implant and subsequent ventricular arrhythmias or inappropriate shocks.

We identified six trials, which assessed the efficacy of cardiac resynchronization therapy with a pacemaker (CRT-P) compared to optimal medical therapy alone (OMT). Three trials with longer followup showed improved survival (all-cause mortality) with CRT-P but those with shorter duration did not find an effect (moderate strength of evidence).There was moderate strength of evidence that CRT-P reduced heart failure hospitalizations and low strength of evidence that CRT-P, compared with OMT, induced ventricular reverse remodeling. Evidence about MLHFQ was insufficient to draw conclusions, and the effect of CRT-P on six-minute hall walk distances compared to optimal medical alone was similarly unclear. Harms associated with CRT-P were as follows: cardiac perforation/tamponade (0–1.6%), pocket hematoma (0.2–9.5%), pneumothorax (0.5–1.5%), device infection (0.7–4.8%), and lead dislodgement (1.7–17%).

Determining predictors of response to CRT was limited by the likely presence of reporting bias. Nevertheless, a left bundle branch block (LBBB) morphology, non-ischemic cardiomyopathy (NICM), and female gender were generally associated with improved outcomes following CRT-D. Sinus rhythm (as compared to atrial fibrillation) and a wider QRS duration were associated with improved outcomes following CRT-D albeit with a lower strength of evidence. There is insufficient evidence to determine predictors of outcomes in patients undergoing CRT-P. However, of the outcomes that were assessed, the ICD function would impact only the mortality endpoint. Therefore similar conclusions as to those noted for CRT-D can be drawn for CRT-P devices for the other, non-mortality endpoints.

The availability of only one trial, with methodological limitations, means that there is insufficient evidence to determine the effectiveness of CRT-D vs. CRT-P. Compared to CRT-P, device infection was slightly more common in patients receiving CRT-D. There was insufficient evidence to draw conclusions on any other harms comparing the two devices.

Figure A Summary of the literature search and screen

* Total number of reasons for exclusion exceeds the number of citations excluded, because citations could be excluded for more than one reason

Figure A. summarizes the results of our searching and screening. We identified 13,015 unique citations and excluded 10,805 of these during the abstract screen. During the full-text screening, we excluded 1032 citations (See Appendix D for list of excluded articles with reason (s) for exclusion). Sixty studies reported in eighty six articles are included in this review.

## Discussion

### Key Findings and the Strength of Evidence

#### Efficacy and Safety of CRT-D (KQ1a, KQ2)

There is convincing evidence that CRT-D devices are effective in reducing heart failure symptoms, improving myocardial function, and reducing hospitalizations for heart failure in patients with an LVEF≤35% and a QRS duration ≥120 ms compared to therapy with an ICD alone. Specifically, we found moderate strength of evidence for benefit of CRT-D versus ICD alone for all-cause mortality in minimally symptomatic patients. This statement is derived from data looking primarily at NYHA class II patients. The applicability of this finding to NYHA class I patients, a population significantly under-represented in studies, is unclear. There is insufficient evidence to determine whether CRT-D devices are effective in improving survival compared to an ICD alone in an advanced heart failure population (NYHA III–IV).

In terms of pre-specified subgroups, there is generally strong evidence that in CRT-D patients (compared to an ICD alone), female gender, a left bundle branch block, and non-ischemic cardiomyopathy are associated with superior outcomes. Sinus rhythm (as opposed to a history of atrial fibrillation) and a wider QRS complex and also associated with superior outcomes in patients undergoing CRT-D implant compared to an ICD alone although the data for this are less compelling. (Table A.)

#### Efficacy and Safety of CRT-P (KQ3a, KQ4)

There is moderate evidence that CRT-P, compared to optimal medical therapy, is effective in improving survival, reducing LVESV, and reducing hospitalizations for heart failure in patients with an LVEF≤35% and a QRS duration ≥120 ms compared to optimal medical therapy alone. These data are largely derived from patients with NYHA class III–IV heart failure. The applicability of these findings to patient with NYHA class I–II heart failure is unclear. We found insufficient evidence about the effect of CRT-P on quality of life, as measured with the MLHFQ, compared to optimal medical therapy alone.

#### Efficacy and Safety of CRT-D versus CRT-P (KQ5, KQ6)

Only one included trial contained both CRT-D and CRT-P arms, and direct comparisons between those arms were lacking. Therefore, there is insufficient evidence to determine the effectiveness of CRT-D compared to CRT-P. In comparing harms between CRT-D and CRT-P devices, there was also insufficient evidence to draw any conclusions except for device infections, which appear to be slightly more common for CRT-D devices.

#### Predictors of Response: CRT-D and CRT-P (KQ1b, KQ3b)

The evidence regarding predictors of a favorable response following CRT varied considerably based on outcome. In addition, the high likelihood of reporting bias qualifies these results. Age was not an important predictor of outcomes in patients receiving CRT-D devices. However, data for very elderly patients (> 75 years of age) were limited. Non-ischemic cardiomyopathy, female gender, and a left bundle branch block morphology were strongly associated with improved outcomes. A history of atrial fibrillation and a narrower QRS duration were predictive of poorer outcomes although the evidence for this was less robust. There was inadequate evidence to determine the predictive nature of chronic kidney disease, left atrial volume, baseline LVEF, body mass index, and left ventricular end-diastolic volume on outcomes following CRT-D implant. There was also insufficient evidence to draw conclusions as to the predictive nature of baseline characteristics in patients receiving a CRT-P device. However, of the outcomes that were assessed, the ICD function would impact only the mortality endpoint. Therefore similar conclusions as to those noted for CRT-D can likely be drawn for CRT-P devices for the other, non-mortality endpoints.

Table A Summary of the strength of evidence for key effectiveness outcomes

Comparisons | All-cause mortality | Hospitalizations for heart failure | Left ventricular end systolic volume (or index) | Minnesota Living with Heart Failure Questionnaire
Cardiac resynchronization therapy with defibrillator vs. ICD alone | Moderate In patients with minimally symptomatic CHF (primarily class NYHA class II), data from the RAFT trial (a larger, slightly more symptomatic population, with a longer followup) demonstrates a mortality benefit, The MADIT-CRT trial did not report a mortality benefit with CRT-D in primarily NYHA class II patients. Long-term followup of a subset of patients demonstrated a mortality benefit in patients with LBBB but not with a non-LBBB and did not report a mortality comparison for the group as a whole. The other trials assessing mortality in minimally symptomatic patients were either too small in size or followup to add significant additional evidence. The trials assessing mortality in patients with NYHA class III–IV symptoms were limited in terms of followup and size, therefore there is insufficient evidence to determine the effect of CRT-D on mortality compared to an ICD alone. | High The large RAFT and MADIT-CRT trials showed a reduction in CHF events for CRT-D compared to an ICD alone. Subgroup analyses from both trials demonstrate the effect to be primarily in patients with LBBB morphology. | High The trials were consistent in demonstrating a reduction in LVESV with CRT-D compared to an ICD alone. Meta-analysis of trials in patients with NYHA I–II (primarily NYHA class II patients), mean difference −22.55 (95% CI, −40.66 to −9.56). | High The current data suggest that CRT-D does not improve QOL in minimally symptomatic patients compared to an ICD alone. The data does suggest a significant improvement in QOL in patients with NYHA class III–IV CHF (mean difference −10.91 (95% CI −12.03 to 7.27).
Cardiac resynchronization therapy with pacemaker vs. optimal medical therapy | Moderate Studies showed statistically significant differences in mortality favoring CRT-P. | Moderate Studies showed fewer hospitalizations in the CRT-P group | Low CRT-P significantly reduced LVESV compared with optimal medical therapy alone. | Insufficient
Cardiac resynchronization therapy with pacemaker or with defibrillator | Insufficient | Low Compared with optimal medical therapy, CRT-P and CRT-D were associated with 44% and 41% reduction in heart failure hospitalizations (not significantly different). | Insufficient | Insufficient

### Relationship of Findings to Existing Literature

Our current review differs from prior reviews in that only studies with patients with an LVEF≤35% and a baseline QRS duration≥120 ms undergoing biventricular pacing were included. These criteria were developed in consultation with our key informants and largely mirror the current appropriate use criteria for CRT from United States guidelines.1 This eliminated the REVERSE, BLOCK CHF, and HOBIPACE trials which included patients with an LVEF>35%.11–13 The criteria also excluded all trials looking at the effects of CRT in a narrow QRS duration population,14–16 and studies of LV only pacing.17, 18 We considered the appropriate control for the CRT-D effectiveness question to be an ICD alone given the compelling data demonstrating improvements in mortality with an ICD that evolved concomitantly with studies of CRT effectiveness. We considered the appropriate control for CRT-P to be optimal medical therapy alone to assess the impact of cardiac resynchronization. We did not assess the comparison of CRT-D to optimal medical therapy as we determined this to be an inappropriate comparison, given the known improvements in mortality by defibrillation. Also, in contrast to several previous reviews, we included only RCTs to assess the questions regarding effectiveness.

In terms of minimally symptomatic patients, the results of our review largely agree with those of prior reviews, which focused on the same population. Similarly, the current review is in agreement with the systematic review performed in 2007 by Mcallister et al., which included studies primarily involving an advanced heart failure population.19 Our review arrived at somewhat different conclusions in terms of the efficacy of CRT-D vs. CRT-P compared to that by Jiang et. al.20 Given that we considered only RCTs for determination of effectiveness, only the COMPANION trial was included in our review, which likely explains the discrepancy in conclusions.3

In our systematic analysis of predictors of outcomes following CRT, many studies assessing the capacity for baseline characteristics to predict responses (defined in many different ways) were identified. The large majority of studies were small (<100 patients) and not properly controlled. At a minimum, we pre-specified that a cohort study addressing our questions about predictors of response to CRT had to include at least gender and either QRS duration or morphology in a multivariate model to address confounding factors. Such criteria eliminated many studies. Despite this, the positive predictive effect noted with LBBB, female gender, non-ischemic cardiomyopathy, a wider QRS duration, and normal sinus rhythm on multiple outcomes was supportive of the similar findings noted from the pre-specified subgroup analyses of the RCTs. There are other potential predictors we did not consider (e.g. lead position). Given the large number of potential predictors in the literature, a review of all predictors was not practical. Our predictors were chosen based on prevailing knowledge of the most important predictors, identified in consultation with our key informants.

Finally, we did not conduct individual patient data meta-analysis to assess predictors meaning that our analyses may suggest that clinically relevant subgroup effects exist, but we are unable to quantify the effects reliably or precisely.

### Applicability

The generalizability of these results is slightly limited. Race was reported very infrequently, prohibiting an assessment of applicability based on racial differences. The majority of patients included in the RCTs were male, although a large focus in sub-studies has been given to the role of CRT in women, given the heightened response to therapy seen in this population. The average age in the RCTs and cohort studies was in the mid 60s although many patients included were in the age range of the elderly Medicare population. There has not been an RCT that specifically enrolled Medicare eligible patients. Also, data for very elderly patients (> 75 years of age) are limited. In cohort studies and subgroup analyses from the RCTs, age was not found to be an important predictor of outcomes. Taken together, the results of our review are generalizable to the Medicare population although given the absence of dedicated RCTs, a definitive statement of generalizability to this population is not possible.

### Limitations of the Comparative Effectiveness Review Process

In addressing the questions of efficacy of CRT-D and CRT-P, several studies potentially of interest were excluded since they were non-randomized. For the questions about the predictors of response to CRT, many retrospective cohort studies were excluded because of a mixed population of CRT-D and CRT-P devices. Attempts were made to contact the authors of such studies to obtain the device-specific data but, in many cases, this was unsuccessful. In addition, many cohorts that contained outcomes of interest were excluded due to failure to control for gender and QRS duration and/or morphology, important baseline confounders. Finally, we did not include prior or conduct new individual patient data meta-analyses to assess predictors. Therefore, our analyses may suggest that clinically relevant subgroup effects exist, but we are unable to quantify the effects reliably or precisely.

### Limitations of the Evidence Base

Multiple, well-conducted RCTs were identified addressing the questions about the efficacy of CRT-D and CRT-P. The majority of patients enrolled in the clinical trials had NYHA class II–IV heart failure symptoms. The applicability of the current findings to class I patients is less clear. In contrast, only the COMPANION trial contained both CRT-D and CRT-P arms.3 However, a direct comparison of the CRT-D to CRT-P arms was not reported for several outcomes. For the questions examining predictors of response to CRT many of the included cohort studies were relatively small. While all studies controlled for gender and either QRS duration or morphology based on our pre-specified inclusion criteria, the remaining variables in the model varied widely between studies. Similarly, many studies used statistical criteria to create their multivariate adjustments, rather than pre-specifying clinical factors known to be important.

### Research Gaps

There is convincing evidence that CRT-D results in reverse ventricular remodeling and improvements in quality of life compared to an ICD alone. However, only two trials showed a mortality benefit of CRT-D over ICD alone. The RAFT trial primarily contained patients with NYHA class II symptoms.6 Long term follow up of the MADIT-CRT trial suggested a mortality benefit in the LBBB subgroup alone but did not report mortality for the cohort as a whole.21 Whether CRT-D results in improved survival compared to an ICD alone in patients with advanced heart failure is unclear.

Several subgroup analyses from RCTs as well as cohort studies demonstrate superior outcomes in patients with a native LBBB compared to a non-LBBB. Subgroup analysis from the MADIT-CRT trial suggested possible harm for CRT-D versus an ICD alone in non-LBBB patients.5, 21 Subgroup analyses from other RCTs suggested little benefit of CRT in non-LBBB patients (but no convincing trend towards harm).6 One important issue with the assessment of CRT efficacy according to QRS morphology is the interaction between QRS duration, another variable with impact on outcome, and morphology. Patients with a LBBB tend to have wider QRS durations than patients with non-LBBBs. Several retrospective studies have attempted to determine the relative impact on outcomes of QRS duration within various QRS morphology groups in patients receiving a CRT device with mixed results.22, 23 There has not been an RCT, which compares CRT to a control in patients with a non-LBBB morphology. Given the lack of such a trial, the ability to conclude definitively that CRT is ineffective or, in fact harmful, in patients with non-LBBB morphology is limited.

Similarly, subgroup analyses from RCTs suggest limited benefit of CRT in patients with atrial fibrillation. Outside the small MUSTIC-AF study, data focused on the AF population are lacking.24 Therefore, the ability to definitively conclude a lack of benefit in patients with AF receiving CRT is not possible.

The effectiveness of CRT-D versus CRT-P in patients with an LVEF≤35% has not been adequately addressed. The COMPANION trial, which included both arms, did not directly compare the CRT types and is therefore inadequate to answer this question definitively.3

## Conclusion

We performed a systematic review to evaluate the efficacy and safety of CRT-D and CRT-P devices as well as predictors of outcomes following implant of such devices. There is convincing evidence that CRT-D is effective with regard to improvements in multiple outcomes compared to an ICD alone in patients with an LVEF≤35% and a QRS duration ≥120ms. These findings are based on patients primarily with NYHA class II–IV heart failure. The applicability of these findings to patients with NYHA class I symptoms is unclear. Similarly, there is convincing evidence that CRT-P is effective in improving multiple endpoints compared to optimal medical therapy alone in the same population. These data are primarily derived from NYHA class III–IV and the applicability to patients with NYHA class I and II is less clear. Female gender, LBBB, a widened QRS duration, sinus rhythm, and non-ischemic cardiomyopathy are associated with improved outcomes following CRT.

## Reference List

1 Heart Failure Society of America (HFSA) practice guidelines. HFSA guidelines for management of patients with heart failure caused by left ventricular systolic dysfunction--pharmacological approaches. J Card Fail. 1999;5(4):357-382. [pmid: 10634677].
2 Abraham WT, Fisher WG, Smith AL, et al. Cardiac resynchronization in chronic heart failure. N Engl J Med. 2002;346(24):1845-1853. [pmid: 12063368].
3 Bristow MR, Saxon LA, Boehmer J, et al. Cardiac-resynchronization therapy with or without an implantable defibrillator in advanced chronic heart failure. N Engl J Med. 2004;350(21):2140-2150. [pmid: 15152059].
4 Cleland JG, Daubert JC, Erdmann E, et al. The effect of cardiac resynchronization on morbidity and mortality in heart failure. N Engl J Med. 2005;352(15):1539-1549. [pmid: 15753115].
5 Moss AJ, Hall WJ, Cannom DS, et al. Cardiac-resynchronization therapy for the prevention of heart-failure events. N Engl J Med. 2009;361(14):1329-1338. [pmid: 19723701].
6 Tang AS, Wells GA, Talajic M, et al. Cardiac-resynchronization therapy for mild-to-moderate heart failure. N Engl J Med. 2010;363(25):2385-2395. [pmid: 21073365].
7 Higgins JPT. Cochrane handbook for systemic reviews of interventions Version 5.1.0. The Cochrane Collaboration. Oxford, England. 2011. Available at: http://handbook.cochrane.org. PMID:.
8 Wells GA. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. 2011. www.ohri.ca/programs/clinical_epidemiology/oxford.asp. 2011.
9 Hayden JA. Assessing bias in studies of prognostic factors. Ann Intern Med. 2013;158(4):280-286. [pmid: 23420236].
10 Agency for Healthcare Research and Quality. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions - AHRQ and the Effective Health Care Program: An Update. Rockville, MD. Agency for Healthcare Research and Quality. 2013. Available at: http://effectivehealthcare.ahrq.gov/ehc/products/457/1163/GradingTheStrengthofEvidence_DraftMethodsChapter_20120625.pdf. 2013. PMID:.
11 Daubert C, Gold MR, Abraham WT, et al. Prevention of disease progression by cardiac resynchronization therapy in patients with asymptomatic or mildly symptomatic left ventricular dysfunction: insights from the European cohort of the REVERSE (Resynchronization Reverses Remodeling in Systolic Left Ventricular Dysfunction) trial. J Am Coll Cardiol. 2009;54(20):1837-1846. [pmid: 19800193].
12 Kindermann M, Hennen B, Jung J, Geisel J, Bohm M, Frohlig G. Biventricular versus conventional right ventricular stimulation for patients with standard pacing indication and left ventricular dysfunction: the Homburg Biventricular Pacing Evaluation (HOBIPACE). J Am Coll Cardiol. 2006;47(10):1927-1937. [pmid: 16697307].
13 Curtis AB, Worley SJ, Adamson PB, et al. Biventricular pacing for atrioventricular block and systolic dysfunction. N Engl J Med. 2013;368(17):1585-1593. [pmid: 23614585].
14 Beshai JF, Grimm RA, Nagueh SF, et al. Cardiac-resynchronization therapy in heart failure with narrow QRS complexes. N Engl J Med. 2007;357(24):2461-2471. [pmid: 17986493].
15 Thibault B, Harel F, Ducharme A, et al. Cardiac resynchronization therapy in patients with heart failure and a QRS complex <120 milliseconds: the Evaluation of Resynchronization Therapy for Heart Failure (LESSER-EARTH) trial. Circulation. 2013;127(8):873-881. [pmid: 23388213].
16 Ruschitzka F, Abraham WT, Singh JP, et al. Cardiac-resynchronization therapy in heart failure with a narrow QRS complex. N Engl J Med. 2013;369(15):1395-1405. [pmid: 23998714].
17 Boriani G, Kranig W, Donal E, et al. A randomized double-blind comparison of biventricular versus left ventricular stimulation for cardiac resynchronization therapy: the Biventricular versus Left Univentricular Pacing with ICD Back-up in Heart Failure Patients (B-LEFT HF) trial. Am Heart J. 2010;159(6):1052-1058.e1. [pmid: 20569719].
18 Thibault B, Ducharme A, Harel F, et al. Left ventricular versus simultaneous biventricular pacing in patients with heart failure and a QRS complex >/=120 milliseconds. Circulation. 2011;124(25):2874-2881. [pmid: 22104549].
19 McAlister FA, Ezekowitz J, Hooton N, et al. Cardiac resynchronization therapy for patients with left ventricular systolic dysfunction: a systematic review. JAMA. 2007;297(22):2502-2514. [pmid: 17565085].
20 Jiang M, He B, Zhang Q. Comparison of CRT and CRT-D in heart failure: systematic review of controlled trials. Int J Cardiol. 2012;158(1):39-45. [pmid: 21262545].
21 Goldenberg I, Kutyifa V, Klein HU, et al. Survival with cardiac-resynchronization therapy in mild heart failure. N Engl J Med. 2014;370(18):1694-1701. [pmid: 24678999].
22 Dupont M, Rickard J, Baranowski B, et al. Differential response to cardiac resynchronization therapy and clinical outcomes according to QRS morphology and QRS duration. J Am Coll Cardiol. 2012;60(7):592-598. [pmid: 22796255].
23 Cleland JG, Abraham WT, Linde C, et al. An individual patient meta-analysis of five randomized trials assessing the effects of cardiac resynchronization therapy on morbidity and mortality in patients with symptomatic heart failure. Eur Heart J. 2013;34(46):3547-3556. [pmid: 23900696].
24 Leclercq C, Walker S, Linde C, et al. Comparative effects of permanent biventricular and right-univentricular pacing in heart failure patients with chronic atrial fibrillation. Eur Heart J. 2002;23(22):1780-1787. [pmid: 12419298].