# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report was reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Sana M. Al-Khatib, M.D., M.H.S.
  Heart Rhythm Specialist and Associate Professor of Medicine
  Division of Medicine – Cardiology, Department of Medicine
  Duke University Medical Center
  Durham, NC
- Daniel B. Kramer, MD, MPH
  Cardiac Electrophysiology
  Cardiac Arrhythmias Specialist
  Beth Israel Deaconess Medical Center
  Boston, MA
- Michael Lauer, M.D.
  Director, Division of Cardiovascular Sciences
  National Heart, Lung, and Blood Institute (NHLBI)
  National Institutes of Health (NIH)
  Bethesda, MD
- Win-Kuang Shen, M.D.
  Mayo Clinic College of Medicine
  Chair, Division of Cardiovascular Diseases Mayo Clinic Arizona
  Scottsdale, AZ
- Lynne Stevenson, M.D.
  Director, Cardiomyopathy and Heart Failure Program
  Harvard Medical School
  Boston, MA