# List of Abbreviations

6MHWD: 6 Minute Hall Walk Distance
AF: Atrial fibrillation
AHRQ: Agency for Healthcare Research and Quality
CABG: Coronary Artery Bypass Grafting
CAG: Coverage and Analysis Group
CARE HF: Cardiac Resynchronization-Heart Failure
CENTRAL: Cochrane Central Register of Controlled Trials
CI: Confidence Interval
CINAHL: Cumulative Index to Nursing and Allied Health Literature
CMS: Centers for Medicare and Medicaid services
COMPANION: Comparison of Medical Therapy, Pacing, and Defibrillation in Heart Failure
CRT: Cardiac resynchronization
CRT-D: Cardiac resynchronization defibrillator
CRT-P: Cardiac resynchronization pacemaker
GFR: Glomerular Filtration Rate
HR: Hazard Ratio
ICD: Implantable Cardiac Defibrillator
ICM: Ischemic Cardiomyopathy
IHD: Ischemic Heart Disease
IS: Inappropriate shocks
IVCD: Intra Ventricular Conduction Delay
KQ: Key question
LAV: Left Atrial Volume
LBBB: Left Bundle Branch Block
LV: Left Ventricle
LVEDV: Left Ventricular End Systolic Volume Index
LVEDVi: Left Ventricular End Systolic Volume Index
LVEF: Left Ventricular Ejection Fraction
LVESV: Left Ventricular End Systolic Volume
LVESVi: Left Ventricular End Systolic Volume Index
MADIT: Multicenter Automatic Defibrillator Implantation Trial–Cardiac Resynchronization Therapy
MASCOT: Management of Atrial fibrillation Suppression in AF-HF Comorbidity Therapy
MeSH: Medical subject headings
MLHFQ: Minnesota Living With Heart Failure Questionnaire
MUSTIC: Multisite Stimulation in Cardiomyopathy
NA: Not Applicable
NICM: Non Ischemic Cardiomyopathy
NR: Not reported
NSIVCD: Non-Specific Intra Ventricular conduction defect
NYHA: New York Heart Association
OMT: Optimal Medical Therapy
OPT: Optimal Pharmacological Therapy
OR: Odds Ratio
PBBBlock: Paced Bundle Branch Block
PICOTS: Population, intervention, comparison, outcome, timing, setting
QOL: Quality of life
QUIPS: Quality In Prognosis Studies
RAFT: Resynchronization–Defibrillation for Ambulatory Heart Failure Trial
RBBB: Right Bundle Branch Block
RCT: Randomized controlled trial
SIP: Scientific Information Packets
SD: Standard deviation
SMART AV: Smart Delay Determined AV Optimization
U.S.: United States
VA: Ventricular Arrhythmia