# Reference List

1 Heart Failure Society of America (HFSA) practice guidelines. HFSA guidelines for management of patients with heart failure caused by left ventricular systolic dysfunction--pharmacological approaches. J Card Fail. 1999;5(4):357-382. [pmid: 10634677].
2 Lloyd-Jones D, Adams RJ, Brown TM, et al. Heart disease and stroke statistics--2010 update: a report from the American Heart Association. Circulation. 2010;121(7):e46-e215. [pmid: 20019324].
3 Abraham WT, Fisher WG, Smith AL, et al. Cardiac resynchronization in chronic heart failure. N Engl J Med. 2002;346(24):1845-1853. [pmid: 12063368].
4 Bristow MR, Saxon LA, Boehmer J, et al. Cardiac-resynchronization therapy with or without an implantable defibrillator in advanced chronic heart failure. N Engl J Med. 2004;350(21):2140-2150. [pmid: 15152059].
5 Cleland JG, Daubert JC, Erdmann E, et al. The effect of cardiac resynchronization on morbidity and mortality in heart failure. N Engl J Med. 2005;352(15):1539-1549. [pmid: 15753115].
6 Moss AJ, Hall WJ, Cannom DS, et al. Cardiac-resynchronization therapy for the prevention of heart-failure events. N Engl J Med. 2009;361(14):1329-1338. [pmid: 19723701].
7 Tang AS, Wells GA, Talajic M, et al. Cardiac-resynchronization therapy for mild-to-moderate heart failure. N Engl J Med. 2010;363(25):2385-2395. [pmid: 21073365].
8 Cazeau S, Leclercq C, Lavergne T, et al. Effects of multisite biventricular pacing in patients with heart failure and intraventricular conduction delay. N Engl J Med. 2001;344(12):873-880. [pmid: 11259720].
9 Birnie DH, Tang AS. The problem of non-response to cardiac resynchronization therapy. Curr Opin Cardiol. 2006;21(1):20-26. [pmid: 16355025].
10 Zareba W, Klein H, Cygankiewicz I, et al. Effectiveness of Cardiac Resynchronization Therapy by QRS Morphology in the Multicenter Automatic Defibrillator Implantation Trial-Cardiac Resynchronization Therapy (MADIT-CRT). Circulation. 2011;123(10):1061-1072. [pmid: 21357819].
11 Adelstein EC, Saba S. Usefulness of baseline electrocardiographic QRS complex pattern to predict response to cardiac resynchronization. Am J Cardiol. 2009;103(2):238-242. [pmid: 19121443].
12 Rickard J, Kumbhani DJ, Gorodeski EZ, et al. Cardiac resynchronization therapy in non-left bundle branch block morphologies. Pacing Clin Electrophysiol. 2010;33(5):590-595. [pmid: 20025703].
13 Peterson PN, Greiner MA, Qualls LG, et al. QRS duration, bundle-branch block morphology, and outcomes among older patients with heart failure receiving cardiac resynchronization therapy. JAMA. 2013;310(6):617-626. [pmid: 23942680].
14 Russo AM, Stainback RF, Bailey SR, et al. ACCF/HRS/AHA/ASE/HFSA/SCAI/SCCT/SCMR 2013 appropriate use criteria for implantable cardioverter-defibrillators and cardiac resynchronization therapy: a report of the American College of Cardiology Foundation appropriate use criteria task force, Heart Rhythm Society, American Heart Association, American Society of Echocardiography, Heart Failure Society of America, Society for Cardiovascular Angiography and Interventions, Society of Cardiovascular Computed Tomography, and Society for Cardiovascular Magnetic Resonance. J Am Coll Cardiol. 2013;61(12):1318-1368. [pmid: 23453819].
15 Epstein AE, DiMarco JP, Ellenbogen KA, et al. 2012 ACCF/AHA/HRS focused update incorporated into the ACCF/AHA/HRS 2008 guidelines for device-based therapy of cardiac rhythm abnormalities: a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines and the Heart Rhythm Society. J Am Coll Cardiol. 2013;61(3):e6-e75. [pmid: 23265327].
16 Linde C, Ellenbogen K, McAlister FA. Cardiac resynchronization therapy (CRT): clinical trials, guidelines, and target populations. Heart Rhythm. 2012;9(8 Suppl):S3-S13. [pmid: 22521934].
17 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2014. Chapters available at: www.effectivehealthcare.ahrq.gov. PMID:.
18 Higgins JPT. Cochrane handbook for systemic reviews of interventions Version 5.1.0. The Cochrane Collaboration. Oxford, England. 2011. Available at: http://handbook.cochrane.org. PMID:.
19 Wells GA. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. 2011. www.ohri.ca/programs/clinical_epidemiology/oxford.asp. 2011. PMID:.
20 Hayden JA. Assessing bias in studies of prognostic factors. Ann Intern Med. 2013;158(4):280-286. [pmid: 23420236].
21 Agency for Healthcare Research and Quality. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions - AHRQ and the Effective Health Care Program: An Update. Rockville, MD. Agency for Healthcare Research and Quality. 2013. Available at: http://effectivehealthcare.ahrq.gov/ehc/products/457/1163/GradingTheStrengthofEvidence_DraftMethodsChapter_20120625.pdf. 2013. PMID:.
22 Cleland JG, Daubert JC, Erdmann E, et al. Longer-term effects of cardiac resynchronization therapy on mortality in heart failure. Eur Heart J. 2006;27(16):1928-1932. [pmid: 16782715].
23 Cleland JG, Freemantle N, Daubert JC, Toff WD, Leisch F, Tavazzi L. Long-term effect of cardiac resynchronisation in patients reporting mild symptoms of heart failure: a report from the CARE-HF study. Heart. 2008;94(3):278-283. [pmid: 17984215].
24 Cleland JG, Calvert MJ, Verboven Y, Freemantle N. Effects of cardiac resynchronization therapy on long-term quality of life: an analysis from the CArdiac Resynchronisation-Heart Failure (CARE-HF) study. Am Heart J. 2009;157(3):457-466. [pmid: 19249415].
25 Ghio S, Freemantle N, Scelsi L, et al. Long-term left ventricular reverse remodelling with cardiac resynchronization therapy: results from the CARE-HF trial. Eur J Heart Fail. 2009;11(5):480-488. [pmid: 19287017].
26 Gras D, Bocker D, Lunati M, et al. Implantation of cardiac resynchronization therapy systems in the CARE-HF trial: procedural success rate and safety. Europace. 2007;9(7):516-522. [pmid: 17540662].
27 Wikstrom G, Blomstrom-Lundqvist C, Andren B, et al. The effects of aetiology on outcome in patients treated with cardiac resynchronization therapy in the CARE-HF trial. Eur Heart J. 2009;30(7):782-788. [pmid: 19168870].
28 Cleland JG, Freemantle N, Erdmann E, et al. Long-term mortality with cardiac resynchronization therapy in the Cardiac Resynchronization-Heart Failure (CARE-HF) trial. Eur J Heart Fail. 2012;14(6):628-634. [pmid: 22552183].
29 Anand IS, Carson P, Galle E, et al. Cardiac resynchronization therapy reduces the risk of hospitalizations in patients with advanced heart failure: results from the Comparison of Medical Therapy, Pacing and Defibrillation in Heart Failure (COMPANION) trial. Circulation. 2009;119(7):969-977. [pmid: 19204305].
30 Carson P, Anand I, O'Connor C, et al. Mode of death in advanced heart failure: the Comparison of Medical, Pacing, and Defibrillation Therapies in Heart Failure (COMPANION) trial. J Am Coll Cardiol. 2005;46(12):2329-2334. [pmid: 16360067].
31 Arshad A, Moss AJ, Foster E, et al. Cardiac resynchronization therapy is more effective in women than in men: the MADIT-CRT (Multicenter Automatic Defibrillator Implantation Trial with Cardiac Resynchronization Therapy) trial. J Am Coll Cardiol. 2011;57(7):813-820. [pmid: 21310317].
32 Barsheshet A, Goldenberg I, Moss AJ, et al. Response to preventive cardiac resynchronization therapy in patients with ischaemic and nonischaemic cardiomyopathy in MADIT-CRT. Eur Heart J. 2011;32(13):1622-1630. [pmid: 21075774].
33 Goldenberg I, Moss AJ, Hall WJ, et al. Predictors of response to cardiac resynchronization therapy in the Multicenter Automatic Defibrillator Implantation Trial with Cardiac Resynchronization Therapy (MADIT-CRT). Circulation. 2011;124(14):1527-1536. [pmid: 21900084].
34 Hsu JC, Solomon SD, Bourgoun M, et al. Predictors of super-response to cardiac resynchronization therapy and associated improvement in clinical outcome: the MADIT-CRT (multicenter automatic defibrillator implantation trial with cardiac resynchronization therapy) study. J Am Coll Cardiol. 2012;59(25):2366-2373. [pmid: 22698490].
35 Ouellet G, Huang DT, Moss AJ, et al. Effect of cardiac resynchronization therapy on the risk of first and recurrent ventricular tachyarrhythmic events in MADIT-CRT. J Am Coll Cardiol. 2012;60(18):1809-1816. [pmid: 23040580].
36 Penn J, Goldenberg I, Moss AJ, et al. Improved outcome with preventive cardiac resynchronization therapy in the elderly: a MADIT-CRT substudy. J Cardiovasc Electrophysiol. 2011;22(8):892-897. [pmid: 21831163].
37 Solomon SD, Foster E, Bourgoun M, et al. Effect of cardiac resynchronization therapy on reverse remodeling and relation to outcome: multicenter automatic defibrillator implantation trial: cardiac resynchronization therapy. Circulation. 2010;122(10):985-992. [pmid: 20733097].
38 Tompkins C, Kutyifa V, McNitt S, et al. Effect on cardiac function of cardiac resynchronization therapy in patients with right bundle branch block (from the Multicenter Automatic Defibrillator Implantation Trial With Cardiac Resynchronization Therapy. Am J Cardiol. 2013;112(4):525-529. [pmid: 23725995].
39 Jamerson D, McNitt S, Polonsky S, Zareba W, Moss A, Tompkins C. Early Procedure-Related Adverse Events by Gender in MADIT-CRT. J Cardiovasc Electrophysiol. 2014;25(9):985-989. [pmid: 24758374].
40 Ruwald MH, Solomon SD, Foster E, et al. Left Ventricular Ejection Fraction Normalization in Cardiac Resynchronization Therapy and Risk of Ventricular Arrhythmias and Clinical Outcomes: Results from the MADIT-CRT Trial. Circulation. 2014. [pmid: 25301831].
41 Goldenberg I, Kutyifa V, Klein HU, et al. Survival with cardiac-resynchronization therapy in mild heart failure. N Engl J Med. 2014;370(18):1694-1701. [pmid: 24678999].
42 St John Sutton MG, Plappert T, Abraham WT, et al. Effect of cardiac resynchronization therapy on left ventricular size and function in chronic heart failure. Circulation. 2003;107(15):1985-1990. [pmid: 12668512].
43 Young JB, Abraham WT, Smith AL, et al. Combined cardiac resynchronization and implantable cardioversion defibrillation in advanced chronic heart failure: the MIRACLE ICD Trial. JAMA. 2003;289(20):2685-2694. [pmid: 12771115].
44 Abraham WT, Young JB, Leon AR, et al. Effects of cardiac resynchronization on disease progression in patients with left ventricular systolic dysfunction, an indication for an implantable cardioverter-defibrillator, and mildly symptomatic chronic heart failure. Circulation. 2004;110(18):2864-2868. [pmid: 15505095].
45 Leclercq C, Walker S, Linde C, et al. Comparative effects of permanent biventricular and right-univentricular pacing in heart failure patients with chronic atrial fibrillation. Eur Heart J. 2002;23(22):1780-1787. [pmid: 12419298].
46 Schuchert A, Muto C, Maounis T, et al. Lead complications, device infections, and clinical outcomes in the first year after implantation of cardiac resynchronization therapy-defibrillator and cardiac resynchronization therapy-pacemaker. Europace. 2013;15(1):71-76. [pmid: 22927665].
47 Birnie DH, Ha A, Higginson L, et al. Impact of QRS morphology and duration on outcomes after cardiac resynchronization therapy: Results from the Resynchronization-Defibrillation for Ambulatory Heart Failure Trial (RAFT). Circ Heart Fail. 2013;6(6):1190-1198. [pmid: 23995437].
48 Gillis AM, Kerr CR, Philippon F, et al. Impact of Cardiac Resynchronization Therapy on Hospitalizations in the Resynchronization-Defibrillation for Ambulatory Heart Failure Trial. Circulation. 2014. [pmid: 24610807].
49 Healey JS, Hohnloser SH, Exner DV, et al. Cardiac resynchronization therapy in patients with permanent atrial fibrillation: results from the Resynchronization for Ambulatory Heart Failure Trial (RAFT). Circ Heart Fail. 2012;5(5):566-570. [pmid: 22896584].
50 Cheng A, Gold MR, Waggoner AD, et al. Potential mechanisms underlying the effect of gender on response to cardiac resynchronization therapy: insights from the SMART-AV multicenter trial. Heart Rhythm. 2012;9(5):736-741. [pmid: 22182496].
51 Gold MR, Birgersdotter-Green U, Singh JP, et al. The relationship between ventricular electrical delay and left ventricular remodelling with cardiac resynchronization therapy. Eur Heart J. 2011;32(20):2516-2524. [pmid: 21875862].
52 Diab IG, Hunter RJ, Kamdar R, et al. Does ventricular dyssynchrony on echocardiography predict response to cardiac resynchronisation therapy? A randomised controlled study. Heart. 2011;97(17):1410-1416. [pmid: 21700757].
53 Garikipati NV, Mittal S, Chaudhry F, et al. Comparison of endovascular versus epicardial lead placement for resynchronization therapy. Am J Cardiol. 2014;113(5):840-844. [pmid: 24406108].
54 Higgins SL, Hummel JD, Niazi IK, et al. Cardiac resynchronization therapy for the treatment of heart failure in patients with intraventricular conduction delay and malignant ventricular tachyarrhythmias. J Am Coll Cardiol. 2003;42(8):1454-1459. [pmid: 14563591].
55 Leclercq C, Cazeau S, Lellouche D, et al. Upgrading from single chamber right ventricular to biventricular pacing in permanently paced patients with worsening heart failure: The RD-CHF Study. Pacing Clin Electrophysiol. Suppl 1. 2007;30:S23-S30. [pmid: 17302711].
56 Lozano I, Bocchiardo M, Achtelik M, et al. Impact of biventricular pacing on mortality in a randomized crossover study of patients with heart failure and ventricular arrhythmias. Pacing Clin Electrophysiol. 2000;23(11 Pt 2):1711-1712. [pmid: 11139906].
57 Pinter A, Mangat I, Korley V, et al. Assessment of resynchronization therapy on functional status and quality of life in patients requiring an implantable defibrillator. Pacing Clin Electrophysiol. 2009;32(12):1509-1519. [pmid: 19765233].
58 Pokushalov E, Romanov A, Prohorova D, et al. Coronary artery bypass grafting with concomitant cardiac resynchronisation therapy in patients with ischaemic heart failure and left ventricular dyssynchrony. Eur J Cardiothorac Surg. 2010;38(6):773-780. [pmid: 20447832].
59 Auricchio A, Gold MR, Brugada J, et al. Long-term effectiveness of the combined minute ventilation and patient activity sensors as predictor of heart failure events in patients treated with cardiac resynchronization therapy: Results of the Clinical Evaluation of the Physiological Diagnosis Function in the PARADYM CRT device Trial (CLEPSYDRA) study. Eur J Heart Fail. 2014. [pmid: 24639140].
60 Bossard M, Sticherling C, Kuhne M, Frey S, Osswald S, Schaer B. Outcome of patients with cardiac resynchronisation defibrillator therapy and a follow-up of at least five years after implant. Swiss Med Wkly. 2014;144:w13938. [pmid: 24573612].
61 Knight BP, Desai A, Coman J, Faddis M, Yong P. Long-term retention of cardiac resynchronization therapy. J Am Coll Cardiol. 2004;44(1):72-77. [pmid: 15234410].
62 Landolina M, Gasparini M, Lunati M, et al. Long-term complications related to biventricular defibrillator implantation: rate of surgical revisions and impact on survival: insights from the Italian Clinical Service Database. Circulation. 2011;123(22):2526-2535. [pmid: 21576653].
63 Luo NS, Yuan WL, Lin YQ, et al. Potential proarrhythmic effect of cardiac resynchronization therapy during perioperative period: data from a single cardiac center. Chin Med J (Engl). 2010;123(17):2295-2298. [pmid: 21034537].
64 Strimel W, Koplik S, Chen HR, Song J, Huang SK. Safety and effectiveness of primary prevention cardioverter defibrillators in octogenarians. Pacing Clin Electrophysiol. 2011;34(7):900-906. [pmid: 21438896].
65 Theuns DA, Thornton AS, Klootwijk AP, et al. Outcome in patients with an ICD incorporating cardiac resynchronisation therapy: differences between primary and secondary prophylaxis. Eur J Heart Fail. 2005;7(6):1027-1032. [pmid: 16109500].
66 Gasparini M, Menozzi C, Proclemer A, et al. A simplified biventricular defibrillator with fixed long detection intervals reduces implantable cardioverter defibrillator (ICD) interventions and heart failure hospitalizations in patients with non-ischaemic cardiomyopathy implanted for primary prevention: the RELEVANT. Eur Heart J. 2009;30(22):2758-2767. [pmid: 19567380].
67 Duray GZ, Israel CW, Pajitnev D, Hohnloser SH. Upgrading to biventricular pacing/defibrillation systems in right ventricular paced congestive heart failure patients: prospective assessment of procedural parameters and response rate. Europace. 2008;10(1):48-52. [pmid: 18077483].
68 Boven NV, Theuns D, Bogaard K, et al. Atrial Fibrillation in Cardiac Resynchronization Therapy with a Defibrillator: A Risk Factor for Mortality, Appropriate and Inappropriate Shocks. J Cardiovasc Electrophysiol. 2013. [pmid: 23889733].
69 Kuhlkamp V. Initial experience with an implantable cardioverter-defibrillator incorporating cardiac resynchronization therapy. J Am Coll Cardiol. 2002;39(5):790-797. [pmid: 11869843].
70 Van Boven N, Bogaard K, Ruiter J, et al. Functional response to cardiac resynchronization therapy is associated with improved clinical outcome and absence of appropriate shocks. J Cardiovasc Electrophysiol. 2013;24(3):316-322. [pmid: 23210664].
71 Haugaa KH, Marek JJ, Ahmed M, et al. Mechanical dyssynchrony after cardiac resynchronization therapy for severely symptomatic heart failure is associated with risk for ventricular arrhythmias. J Am Soc Echocardiogr. 2014;27(8):872-879. [pmid: 24798865].
72 Masoudi FA, Mi X, Curtis LH, et al. Comparative effectiveness of cardiac resynchronization therapy with an implantable cardioverter-defibrillator versus defibrillator therapy alone: a cohort study. Ann Intern Med. 2014;160(9):603-611. [pmid: 24798523].
73 Gopalamurugan AB, Ganesha Babu G, Rogers DP, et al. Is CRT pro-arrhythmic? A comparative analysis of the occurrence of ventricular arrhythmias between patients implanted with CRTs and ICDs. Front Physiol. 2014;5:334. [pmid: 25278901].
74 Vado A, Menardi E, Rossetti G, Ballari G, Feola M, Bobbio M. Single-center experience of a quadripolar pacing lead for cardiac resynchronization therapy. J Interv Card Electrophysiol. 2014;39(2):161-165. [pmid: 24293178].
75 Wollmann CG, Lawo T, Kuhlkamp V, et al. Implantable defibrillators with enhanced detection algorithms: detection performance and safety results from the PainFree SST study. Pacing Clin Electrophysiol. 2014;37(9):1198-1209. [pmid: 24665992].
76 Ricci RP, Pignalberi C, Landolina M, et al. Ventricular rate monitoring as a tool to predict and prevent atrial fibrillation-related inappropriate shocks in heart failure patients treated with cardiac resynchronisation therapy defibrillators. Heart. 2014;100(11):848-854. [pmid: 24682569].
77 Gras D, Leclercq C, Tang AS, Bucknall C, Luttikhuis HO, Kirstein-Pedersen A. Cardiac resynchronization therapy in advanced heart failure the multicenter InSync clinical study. Eur J Heart Fail. 2002;4(3):311-320. [pmid: 12034157].
78 Krahn AD, Snell L, Yee R, Finan J, Skanes AC, Klein GJ. Biventricular pacing improves quality of life and exercise tolerance in patients with heart failure and intraventricular conduction delay. Can J Cardiol. 2002;18(4):380-387. [pmid: 11992131].
79 Mortensen PT, Sogaard P, Mansour H, et al. Sequential biventricular pacing: evaluation of safety and efficacy. Pacing Clin Electrophysiol. 2004;27(3):339-345. [pmid: 15009860].
80 Stahlberg M, Braunschweig F, Gadler F, Karlsson H, Linde C. Three year outcome of cardiac resynchronization therapy: a single center evaluation. Pacing Clin Electrophysiol. 2005;28(10):1013-1017. [pmid: 16221256].
81 Niu HX, Hua W, Wang FZ, Zhang S, Chen KP, Chen X. Complications of cardiac resynchronization therapy in patients with congestive heart failure. Chin Med J (Engl). 2006;119(6):449-453. [pmid: 16584641].
82 de Cock CC, van Campen CM, Visser CA. Major dissection of the coronary sinus and its tributaries during lead implantation for biventricular stimulation: angiographic follow-up. Europace. 2004;6(1):43-47. [pmid: 14697725].
83 Azizi M, Castel MA, Behrens S, Rodiger W, Nagele H. Experience with coronary sinus lead implantations for cardiac resynchronization therapy in 244 patients. Herzschrittmacherther Elektrophysiol. 2006;17(1):13-18. [pmid: 16547655].
84 Takaya Y, Noda T, Nakajima I, et al. Electrocardiographic predictors of response to cardiac resynchronization therapy in patients with intraventricular conduction delay. Circ. J. 2014;78(1):71-77. [pmid: 24162927].
85 Verbrugge FH, De Vusser P, Rivero-Ayerza M, et al. Cardiac resynchronization therapy with or without defibrillator: experience from a high-volume Belgian implantation centre. Acta Cardiol. 2013;68(1):37-45. [pmid: 23457908].
86 Killu AM, Wu JH, Friedman PA, et al. Outcomes of cardiac resynchronization therapy in the elderly. Pacing Clin Electrophysiol. 2013;36(6):664-672. [pmid: 23252710].
87 Verbrugge FH, Dupont M, De Vusser P, et al. Response to cardiac resynchronization therapy in elderly patients (>/=70 years) and octogenarians. Eur J Heart Fail. 2013;15(2):203-210. [pmid: 23002114].
88 Swindle JP, Rich MW, McCann P, Burroughs TE, Hauptman PJ. Implantable cardiac device procedures in older patients: use and in-hospital outcomes. Arch Intern Med. 2010;170(7):631-637. [pmid: 20386008].
89 Romeyer-Bouchard C, Da Costa A, Dauphinot V, et al. Prevalence and risk factors related to infections of cardiac resynchronization therapy devices. Eur Heart J. 2010;31(2):203-210. [pmid: 19875388].
90 Bilchick KC, Kamath S, DiMarco JP, Stukenborg GJ. Bundle-branch block morphology and other predictors of outcome after cardiac resynchronization therapy in Medicare patients. Circulation. 2010;122(20):2022-2030. [pmid: 21041691].
91 Mascioli G, Padeletti L, Sassone B, et al. Electrocardiographic criteria of true left bundle branch block: a simple sign to predict a better clinical and instrumental response to CRT. Pacing Clin Electrophysiol. 2012;35(8):927-934. [pmid: 22651702].
92 Shen X, Aronow WS, Holmberg MJ, et al. Cardiac resynchronization therapy in patients with intrinsic and right ventricular pacing-induced left bundle branch block pattern. Am J Ther. 2009;16(6):e44-e50. [pmid: 19940605].
93 Shen X, Nair CK, Aronow WS, et al. A patient selection score for cardiac resynchronization therapy. Echocardiography. 2011;28(2):188-195. [pmid: 21276075].
94 Rickard J, Cheng A, Spragg D, et al. QRS narrowing is associated with reverse remodeling in patients with chronic right ventricular pacing upgraded to cardiac resynchronization therapy. Heart Rhythm. 2013;10(1):55-60. [pmid: 23000040].
95 Leong DP, Hoke U, Delgado V, et al. Right ventricular function and survival following cardiac resynchronisation therapy. Heart. 2013;99(10):722-728. [pmid: 23315608].
96 Niebauer MJ, Rickard J, Polakof L, Tchou PJ, Varma N. QRS frequency characteristics help predict response to cardiac resynchronization in left bundle branch block less than 150 milliseconds. Heart Rhythm. 2014. [pmid: 25068573].
97 Shen X, Aronow WS, Nair CK, et al. Are the extent, location, and score of segmental wall motion abnormalities related to cardiac resynchronization therapy response?. Echocardiography. 2009;26(10):1136-1145. [pmid: 19725853].
98 Shanks M, Delgado V, Ng AC, et al. Clinical and echocardiographic predictors of nonresponse to cardiac resynchronization therapy. Am Heart J. 2011;161(3):552-557. [pmid: 21392611].
99 Shen X, Aronow WS, Holmberg MJ, et al. Cardiac resynchronization therapy in patients with intrinsic and right ventricular pacing-induced left bundle branch block pattern. Am J Ther. 2009;16(6):e44-e50. [pmid: 19940605].
100 Stabile G, Solimene F, Bertaglia E, et al. Long-term outcomes of CRT-PM versus CRT-D recipients. Pacing Clin Electrophysiol. Suppl 1. 2009;32:S141-S145. [pmid: 19250079].
101 Zhang Q, van Bommel RJ, Fung JW, et al. Tissue Doppler velocity is superior to strain imaging in predicting long-term cardiovascular events after cardiac resynchronisation therapy. Heart. 2009;95(13):1085-1090. [pmid: 19363024].
102 Daubert C, Gold MR, Abraham WT, et al. Prevention of disease progression by cardiac resynchronization therapy in patients with asymptomatic or mildly symptomatic left ventricular dysfunction: insights from the European cohort of the REVERSE (Resynchronization Reverses Remodeling in Systolic Left Ventricular Dysfunction) trial. J Am Coll Cardiol. 2009;54(20):1837-1846. [pmid: 19800193].
103 Kindermann M, Hennen B, Jung J, Geisel J, Bohm M, Frohlig G. Biventricular versus conventional right ventricular stimulation for patients with standard pacing indication and left ventricular dysfunction: the Homburg Biventricular Pacing Evaluation (HOBIPACE). J Am Coll Cardiol. 2006;47(10):1927-1937. [pmid: 16697307].
104 Curtis AB, Worley SJ, Adamson PB, et al. Biventricular pacing for atrioventricular block and systolic dysfunction. N Engl J Med. 2013;368(17):1585-1593. [pmid: 23614585].
105 Beshai JF, Grimm RA, Nagueh SF, et al. Cardiac-resynchronization therapy in heart failure with narrow QRS complexes. N Engl J Med. 2007;357(24):2461-2471. [pmid: 17986493].
106 Thibault B, Harel F, Ducharme A, et al. Cardiac resynchronization therapy in patients with heart failure and a QRS complex <120 milliseconds: the Evaluation of Resynchronization Therapy for Heart Failure (LESSER-EARTH) trial. Circulation. 2013;127(8):873-881. [pmid: 23388213].
107 Ruschitzka F, Abraham WT, Singh JP, et al. Cardiac-resynchronization therapy in heart failure with a narrow QRS complex. N Engl J Med. 2013;369(15):1395-1405. [pmid: 23998714].
108 Boriani G, Kranig W, Donal E, et al. A randomized double-blind comparison of biventricular versus left ventricular stimulation for cardiac resynchronization therapy: the Biventricular versus Left Univentricular Pacing with ICD Back-up in Heart Failure Patients (B-LEFT HF) trial. Am Heart J. 2010;159(6):1052-1058.e1. [pmid: 20569719].
109 Thibault B, Ducharme A, Harel F, et al. Left ventricular versus simultaneous biventricular pacing in patients with heart failure and a QRS complex >/=120 milliseconds. Circulation. 2011;124(25):2874-2881. [pmid: 22104549].
110 McAlister FA, Ezekowitz J, Hooton N, et al. Cardiac resynchronization therapy for patients with left ventricular systolic dysfunction: a systematic review. JAMA. 2007;297(22):2502-2514. [pmid: 17565085].
111 Jiang M, He B, Zhang Q. Comparison of CRT and CRT-D in heart failure: systematic review of controlled trials. Int J Cardiol. 2012;158(1):39-45. [pmid: 21262545].
112 Adabag S, Roukoz H, Anand IS, Moss AJ. Cardiac resynchronization therapy in patients with minimal heart failure: a systematic review and meta-analysis. J Am Coll Cardiol. 2011;58(9):935-941. [pmid: 21851882].
113 Bryant AR, Wilton SB, Lai MP, Exner DV. Association between QRS duration and outcome with cardiac resynchronization therapy: a systematic review and meta-analysis. J Electrocardiol. 2013;46(2):147-155. [pmid: 23394690].
114 Ganesan AN, Brooks AG, Roberts-Thomson KC, Lau DH, Kalman JM, Sanders P. Role of AV nodal ablation in cardiac resynchronization in patients with coexistent atrial fibrillation and heart failure a systematic review. J Am Coll Cardiol. 2012;59(8):719-726. [pmid: 22340263].
115 Garg N, Thomas G, Jackson G, et al. Cardiac resynchronization therapy in CKD: a systematic review. Clin J Am Soc Nephrol. 2013;8(8):1293-1303. [pmid: 23660183].
116 Hess PL, Jackson KP, Hasselblad V, Al-Khatib SM. Is cardiac resynchronization therapy an antiarrhythmic therapy for atrial fibrillation? A systematic review and meta-analysis. Curr Cardiol Rep. 2013;15(2):330. [pmid: 23299710].
117 Lubitz SA, Leong-Sit P, Fine N, Kramer DB, Singh J, Ellinor PT. Effectiveness of cardiac resynchronization therapy in mild congestive heart failure: systematic review and meta-analysis of randomized trials. Eur J Heart Fail. 2010;12(4):360-366. [pmid: 20335354].
118 McAlister FA, Ezekowitz JA, Wiebe N, et al. Systematic review: cardiac resynchronization in patients with symptomatic heart failure. Ann Intern Med. 2004;141(5):381-390. [pmid: 15353430].
119 Nery PB, Ha AC, Keren A, Birnie DH. Cardiac resynchronization therapy in patients with left ventricular systolic dysfunction and right bundle branch block: a systematic review. Heart Rhythm. 2011;8(7):1083-1087. [pmid: 21300176].
120 Proietti R, Manzoni GM, Cravello L, Castelnuovo G, Bernier ML, Essebag V. Can cardiac resynchronization therapy improve cognitive function? A systematic review. Pacing Clin Electrophysiol. 2014;37(4):520-530. [pmid: 24372257].
121 Santangeli P, Di Biase L, Pelargonio G, et al. Cardiac resynchronization therapy in patients with mild heart failure: a systematic review and meta-analysis. J Interv Card Electrophysiol. 2011;32(2):125-135. [pmid: 21594629].
122 Tu R, Zhong G, Zeng Z, et al. Cardiac resynchronization therapy in patients with mild heart failure: a systematic review and meta-analysis of randomized controlled trials. Cardiovasc Drugs Ther. 2011;25(4):331-340. [pmid: 21750900].
123 van Rees JB, de Bie MK, Thijssen J, Borleffs CJ, Schalij MJ, van Erven L. Implantation-related complications of implantable cardioverter-defibrillators and cardiac resynchronization therapy devices: a systematic review of randomized clinical trials. J Am Coll Cardiol. 2011;58(10):995-1000. [pmid: 21867832].
124 Wilton SB, Leung AA, Ghali WA, Faris P, Exner DV. Outcomes of cardiac resynchronization therapy in patients with versus those without atrial fibrillation: a systematic review and meta-analysis. Heart Rhythm. 2011;8(7):1088-1094. [pmid: 21338711].
125 Dupont M, Rickard J, Baranowski B, et al. Differential response to cardiac resynchronization therapy and clinical outcomes according to QRS morphology and QRS duration. J Am Coll Cardiol. 2012;60(7):592-598. [pmid: 22796255].
126 Cleland JG, Abraham WT, Linde C, et al. An individual patient meta-analysis of five randomized trials assessing the effects of cardiac resynchronization therapy on morbidity and mortality in patients with symptomatic heart failure. Eur Heart J. 2013;34(46):3547-3556. [pmid: 23900696].