# Acknowledgments

We would like to thank Allen Zhang and Elisabeth Haberl Nannes for their assistance in data abstraction, Lisa Wilson for conducting meta-analysis and Eric Vohr for copy editing. We would also like to thank the Peer Reviewers, the Task Order Officers, and representatives from CMS.