# Results

## Key Question 1 Do different management strategies or different methods of removal of the lesion lead to different outcomes?

We examined the evidence for the effect of different management strategies on four outcomes: 1) morbidity and mortality from SCC; 2) incidence of SCC; 3) number and duration of AKs; and 4) quality of life related to side effects and complications of treatment.

Morbidity and mortality from SCC No studies examined how different methods of treatment of AKs affected morbidity and mortality from SCC.

Incidence of SCC. There are data from randomized trials about the effect of sun protection, diet, and chemoprevention on the course of AKs and the incidence of SCC. However, there are no comparable data on the efficacy of destruction, topical therapy, or other treatments to control AKs.

Sunscreen use and, probably, sun avoidance can reduce the incidence of AKs and increase the regression rate. In two randomized trials, one in Texas and one in Australia, daily use of sunscreen reduced the incidence of AK45, 61, 62 The Texas trial, rated as poor quality, was small (53 patients with AK), had a 69 percent rate of completion of the 2-year followup period, and was not analyzed by intention-to-treat.61 The first Australian study45 enrolled 588 subjects who had from 1 to 30 AKs (mean 8 or 9 per patient). A total of 431 subjects (73 percent) completed the goal of 7 months of followup. This trial was rated fair-quality because the results were not analyzed by intention-to-treat. Among those who completed the trial, the mean number of AKs rose by one AK per patient in the placebo group and decreased by 0.6 AK per patient in the sunscreen group. The regression rates for AKs present at the first examination were 25 percent in the sunscreen group and 18 percent in the placebo group; for all AKs, the regression rates were 28 percent (sunscreen group) versus 20 percent (placebo). In a subsequent, good-quality trial,62 sunscreen reduced the incidence of SCC by 18 percent.

One randomized trial evaluated the efficacy of a low-fat diet in controlling AKs.63 In the trial, 133 patients with skin cancer were randomized to either a low-fat diet or usual care. In the first year of followup, the control group was diagnosed to have four times as many AKs as the low-fat group. Over 2 years of followup, patients in the low-fat group had a significant reduction in skin cancers. Rates of skin cancer began to diverge after 16 months; in the last 8 months of the followup period (months 17–24), the control group had 0.26 cancers per patient, versus only 0.02 in the intervention group. Using the USPSTF criteria for study quality, this trial was rated “poor-quality” because it did not describe the method of randomization or the comparability of the control and intervention groups at baseline, did not use intention-to-treat analysis, and did not describe the results in adequate detail to evaluate the appropriateness of the statistical methods.

Three randomized trials have evaluated dietary supplements containing retinol or beta-carotene to prevent SCC and reduce the incidence of AKs. In one good-quality trial, beta-carotene had no effect on the incidence of AK or SCC. A randomized trial of a daily oral retinol supplement showed no effect in patients at high risk of SCC, but in a similar trial in moderate-risk patients, retinol reduced the incidence of first new squamous cell skin cancers by 32 percent.64, 65 Moderate-risk subjects had a history of at least 10 actinic keratoses and at most two prior skin cancers. Retinol was particularly effective in patients who were 63 years of age or older (19 percent vs. 13 percent, number-needed-to-treat [NNT]=17) and in those who had a history of one SCC in the past (21 percent vs. 12 percent, NNT=11).

Number and duration of AKs. Table 2 summarizes experimental and observational studies of the effect of treatment on the number and duration of AKs. Most of these studies recruited patients with multiple AKs from dermatologic referral clinics.

Cryosurgery. One frequently cited case series, conducted in a dermatology clinic based in a tertiary hospital in New Orleans, reported that, in 70 patients followed for 1 year to 8.5 years, only 12 of 1,018 AKs treated with cryosurgery recurred.66

Photodynamic Therapy. One pilot study and two multicenter phase 3 trials examined the efficacy of photodynamic therapy. In the pilot study, 40 patients undergoing photodynamic therapy, placebo (the vehicle) was compared with 10 percent, 20 percent, or 30 percent ALA for photosensitization.67 Patients in all groups were exposed to the same light source after sensitization. In the group that received 30 percent ALA, 91 percent of AKs on the face or scalp responded completely (vs. 0 with placebo), and 45 percent of AKs on the trunk and extremities responded completely (versus 6 percent with placebo). In the group that received 20 percent ALA, 78 percent of AKs on the face and scalp and 38 percent of those on the trunk and extremities resolved completely. For those who received 10 percent ALA, 61 percent of AKs on the face and scalp, and 30 percent of those on the trunk and extremities, resolved completely.

Two multicenter phase 3 trials of 243 patients with 4 to 15 AKs compared one or two photodynamic treatments using a 20% ALA solution to placebo (vehicle).68 ALA was applied to specific lesions on the face and scalp that were subsequently irradiated with blue light. By 3 months after initial treatment, 88 percent of ALA-treated patients had at least 75 percent clearance of their AKs, versus 20 percent in the placebo group.

Topical therapy. Five reports from four controlled trials 69–73 and two case series53, 74 examined the efficacy of 5-FU. None of these compared 5-FU to a placebo. In these trials, 5-FU eliminated 75–80 percent of AKs initially present. In one study,74 the results of using 1 percent 5-FU and 5 percent 5-FU were similar. In some trials,69, 74 a longer course of treatment was needed to treat AKs on the hand (where 5-FU is less efficacious) than on the face or scalp.

Two of these trials reported results at followup periods longer than 6 months.71–73 The longest followup evaluation of 5-FU treatment was published in 1972;^74^ it reported that 25 percent of patients had recurrent or new AKs within 2 years of treatment, and 50 percent within 3 years. In a trial of 15 patients performed in the 1990s, eight were available for evaluation 32 months after treatment with 5-FU on one side of the face and TCA peel on the other side.71, 73 At 32 months, 5-FU reduced the mean number of AKs from 18 before treatment to 10. In one case series patients were treated with 5-FU 1–2 days a week for an average of 6.7 weeks. The first six of 11 patients reaching the 9-month post-treatment marker retained an 86 percent clearance of actinic keratoses.53 In the second series, patients were treated with 1 percent 5-FU; at 2-year followup, 25 percent of one cohort and 40 percent of another required re-treatment with 5-FU for recurrence of AKs.74

A sixth report75 examines a newer formulation of once daily 0.5% 5-FU cream. Two phase-3 trials described in an FDA document reported short-term results. One month after a 4-week course of treatment, 64% and 78% of patients had at least 75% fewer lesions on the face and anterior scalp.

Three controlled trials examined the efficacy of tretinoin in the treatment of AKs.70, 76, 77 One study compared the efficacy of tretinoin and 5-FU vs. 5-FU alone on the upper extremity. The side treated with 5-FU plus tretinoin reduced the mean number of AKs per patient from 15.7 to 3.4.^70^ In the other two studies, tretinoin reduced the number of AKs more effectively than placebo.76, 77

Clinical trials of diclofenac sodium gel were conducted by the manufacturer with data submitted for FDA approval78 but not available in publication. A total of 427 patients who had 5 or more AKs per area of interest were treated with topical diclofenac for 30 to 90 days. Assessment at 30 days after completion of treatment revealed 39 percent of AKs on the forehead and 47 percent of AKs on the face were not visible, versus approximately 20 percent for the placebo group.

Resurfacing. Five controlled trials evaluated the efficacy of chemical peels.71, 73, 79–81 In one controlled trial glycolic acid, which is a superficial chemical peel, reduced the mean number of AKs from 13.7 to 11.6 at 6-month followup.79 In another trial comparing two medium-depth peels, independent investigators evaluated overall improvement of AKs at 2 months and assigned a clinical response score of "fair-good" to those who had a peel with TCA and glycolic acid and a score of "fair" to those who had a peel with TCA and Jessner's solution.80 In one controlled trial of 15 patients, a medium-depth peel with TCA was as effective as initial treatment with 5-FU.71 Nine of the 15 patients preferred the peel to 5-FU.71

In a case series conducted in a community-based practice in Florida, 373 patients with extensive AKs (a total of 34,604) were treated with extensive cryosurgery (“cryopeeling”) and re-examined 6 months or longer after treatment.81 At 6 months, 336 patients (90 percent) were rechecked and there was a 4 percent recurrence rate of AK. A total of 167 patients (45 percent) were rechecked again between 6 and 12 months; these had a recurrence rate of 9 percent. By 12–18 months, when 124 patients (33 percent) were available for followup, there was a 12 percent rate of new or recurrent AK; at 2 years, this rate was 18 percent, but fewer than 25 percent of the original series was available for followup. Thirty-three patients developed SCC. Using an expected rate of progression of 1 per 1,000 AKs per year, or approximately 34 per year for the entire sample, the author concludes that the observed rate of progression to SCC was lower than expected. However, the high rate of attrition and the lack of a control group make it impossible to determine whether or not this is true. The article did not use appropriate statistical methods to estimate the rate of development of SCC based on the size of the remaining sample when they occurred (that is, after appropriately censoring patients lost to followup). As a result, it is not possible to calculate an accurate rate of progression based on the data presented in the article. If the rate of SCC were less than expected, it is unclear whether this reduction was due to the initial cryopeeling; to subsequent monitoring to detect and remove new and recurrent AKs, or to the advice patients received to use sunscreen and retin-A.

In a case series of patients undergoing dermabrasion, 22 of 23 subjects had no AKs after 1 year and 19 of 23 had no AKs 2 years after treatment.82 At 3 years, 15 of 19 (64 percent) patients available for followup had no AKs. No SCCs were found (5 BCCs seen after 4 years).

Quality of life related to side effects and complications of treatment. We described the patient experience and adverse effects of each treatment in Appendix 1. The adverse effects are generally well-known, and play a major role in management. Morbidity from treatments, primarily pain and short-term effects on appearance, can affect compliance and patient preferences among treatment alternatives. If these effects are strong, differences in efficacy (how well a treatment works under controlled, experimental conditions) may be overwhelmed by differences in effectiveness (how well a treatment works in actual practice).

Despite the major role adverse effects play, their effect on decision-making in practice has not been studied. As shown in Table 2, most of the treatment studies provided little or no information on the frequency or severity of adverse effects or on patients’ preferences among treatments; those that do did not use systematic methods to assess the frequency, duration, or severity of side effects. None of the studies used global or diseaes-specific measures to assess the impact of treatment on health-related quality of life.

## Key Question 2 What is the natural history of actinic keratosis?

What is the incidence and regression rate of AKs? The incidence rate and spontaneous regression rate of AKs play a role in deciding how often to treat or monitor patients. For example, even if a course of treatment destroys all AKs present at the time, the patient will need to be treated again if new AKs develop rapidly. Also, the benefit of destroying a lesion is reduced if there is a high chance that the lesion would have regressed spontaneously if left alone.

Prospective, longitudinal studies of the incidence of AKs are summarized in Table 3. One of these was conducted in South Wales, Great Britain,21, the others in Australia.1, 16, 59, 83 All of these studies attempted to recruit samples representative of the general population in a particular community. In the study from Wales, the initial prevalence of AKs (23 percent); the number of AKs per subject initially (2); the overall incidence of AK in 1 year (12.6 percent); and the incidence among those who had no AKs initially (8.8 percent) were all lower than in the Australian studies. In the Australian studies, overall about 40 percent of subjects had new AKs during the followup period of approximately 1 year. Close to 20 percent of men and 7 percent of women who did not have an AK initially developed one or more during this period.

Table 3 Incidence of actinic keratosis

Author, Year | Study sample and setting | Instruments | Length of followup | Followup rates | Initial prevalence of AK | Initial AKs per person | Incidence of new AKs during followup | | Regression rate | Squamous cell cancer
| | | | | | mean (range) | all subjects | newly affected subjects | | prevalence | incidence
| | | | | | | | | % of lesions (rate per 1k/yr) | | overall | in those with AK
Harvey, 1996 | Random sample of subjects age 60 years or older, South Glamorgan, Wales. | Detailed questionnaire and examination of face, head, neck, arms, and legs (below the knee) | 1–2 years | 70.7% of eligible subjects were seen at visit 1; of these, 79.3% of eligible subjects were seen at visit 2. | 23.0% | 2 (1–17) | 12.6% | 8.8% | 21% (1111034 188/1000) | 0.002 | 0.0% | 0.0%
Marks, 1986 | 1040 people age 40 years or older, Maryborough, Australia | Questionnaire and examination of face, head, neck, hands, and forearms. | 1 year | 100% (presumably only those who completed followup were reported); 3 patients who had treatment for 11 AKs were excluded. | 59.2% | 7.7 | 43.4% | 19.1% | 25.9% | NR | NR | 1.6%
Marks, 1988; Marks, 1989 | Population-based sample of 2,669 people over 40 (mean age 60.7), Maryborough, Australia | Demographic variables and examination of face, head, neck, hands, and forearms. | 1–5 years | 81% of eligible subjects were seen at visit 1; 74% of these were seen at visit 2 or higher. | 61.1% | 8.4 | NR | NR | NR | 0.004 | overall: 0.66% age >70:1%
Frost, 2000 | 96 adults 30–69 years, population-based, Nambour, Australia | Demographic variables and examination of face, head, neck, hands, and forearms. | 14–18 months | 93% of scheduled visits were completed; 7 patients had treatment for 93 Aks (6% of total AKs in the study). Treatment of 2 men accounted for 73 of these. | 46% (83% in men 60–69) | 5 (1–50 or more) | 39.3% | 15% (men) 7% (women) | 74% for prevalent AKs; 29% for incident AKs. | NR | 0.0% | 0.0%

AK--actinic keratosis, NR--not reported

AKs can regress. In the first two studies in Table 3, the regression rates of AKs were 21 percent and 25.9 percent per year. In the second study, regression of AKs was strongly associated with outdoor work in patients age 40–49 years and 70–79 years, and 50 percent more likely in those who “never burn, tan easily” compared with those who burn.59 The third study, which is the most recent, reported rates for prevalent and incident AKs. This study used frequent followup visits to examine the natural history of AKs more thoroughly than other studies.83 Subjects were a subset of participants in the Nambour randomized trial not assigned to the sunscreen arm of the trial (49 percent were receiving supplemental beta-carotene and 51 precent placebo). Patients were randomly assigned to examinations every 2 months or every 6 months. AKs that were present on the first examination (prevalent lesions) had a higher regression rate (74 percent) than those that were not present on the first examination but developed before a later visit (29 percent). Over the course of a year, 15 percent of the prevalent AKs that regressed were found to recur later. This finding raises the possibility that a lesion that “regresses” is still present, but is not visible on examination. It is unknown whether lesions that are not visible are still capable of progressing to SCC.

In patients with actinic keratoses, what is the expected incidence of progression to invasive squamous cell carcinoma with and without removal of the lesion? The rate at which AKs progress to squamous cell cancer is a key parameter in devising a strategy for treatment or monitoring. Confusion about the likelihood of progression, and about its timing, is longstanding, as these quotations from two textbooks published in 1983 and 1985 exhibit:

Malignant change occurs in a small minority of cases, the developing squamous cell carcinoma being very slow growing, and with little tendency to metastasize. Such a change is only likely several years after the onset of the lesion. 84

Because they undergo malignant transformation to squamous cell carcinoma , in 20 percent of cases or more, they merit careful, thorough removal.85(The 20 percent figure dates to a series of cases published in the 1930s.86)

There are still very few sources of data to measure the rate at which AKs progress to SCC. Two publications from Marks1, 59 report the rate of progression from AK to SCC, and Dodson6 presents a mathematical model extending data from Marks’ 1988 study to 10 years of followup. In the first study by Marks,59 1,040 Maryborough residents, 616 of whom had AKs, were followed for 1 year (see Table 3). Three of the 616 subjects with AKs underwent treatment during the year, but the other 613 subjects were re-examined 1 year later without intervening treatment. Ten of these 613 subjects (1.6 percent) developed SCCs during the year of followup. Among the 424 who did not have AKs initially, two developed SCC (0.47 percent). In this study, the authors did not attempt to link SCC to specific AKs. Assuming that, in the group that had AKs initially, all of the SCC arose from AKs, one in 429 AKs progressed to SCC in 1 year.

In the second Maryborough study,1 1,689 subjects from the general population (mean age 60.7 years) were invited to attend annual examinations for 5 years (see Table 3). For this study, in contrast to the earlier Maryborough study, the investigators used a grid map to record the location of AKs so that this could be correlated with the location of SCCs found on subsequent visits. As in the first study, the authors told the patients that they did not need to seek treatment for their AKs, but asked them to tell the investigators if they did. However, in this publication the authors did not report how many patients or lesions were treated. A total of 21,905 AKs were eligible for observation.

Over the course of followup, 28 SCCs in 26 people developed. Ten of these occurred at the site where an AK had been recorded 1 year earlier and seven on a site that was clinically normal a year earlier. In the other 11, the investigators could not determine whether the SCC arose from a preexisting lesion. If one assumes that the 11 doubtful cases all arose from AKs, the yearly rate of progression from AK to SCC was 1 in 1,042; a more conservative figure, assuming that 6 or 7 of the 11 originated in AKs, would be 1 in 1,333. For the entire sample, 1 in 152 subjects developed an SCC per year of observation. For the subset of subjects over 70 years of age, 1 in 100 developed an SCC per year of observation.

Another longitudinal study,21 listed in Table 3, provides some additional support for the view that the annual rate of progression is relatively low. In that study, no SCCs developed over 557 person-years of followup without treatment of approximately 2,000 AKs. The authors calculated a confidence interval for the rate of progression of 0–11 per 1,000 AKs per year. No SCCs developed in the last study in Table 3,83 but because the sample size was only 96, this study provides no additional evidence regarding the rate of progression.

Dodson used Marks’ data to estimate the likelihood that an AK will progress over 10 years.6 His calculation assumes that each AK has the same chance of progressing, and that the rate of progression is constant over many years. For example, consider a typical patient who has eight AKs. Based on a yearly rate of progression of 24 per 10,000—the rate from Marks’ earlier study—over 10 years, the chance that one of these eight AKs would progress to SCC is 17 percent. For the first year only, 417 AKs would have to be treated to prevent one SCC (10,000/24 = 417). Over 10 years, however, treating the AKs in the first year in all patients would prevent one SCC in 10 years for every 46 AKs treated.

Dodson’s analysis has several limitations. First, the high rate of regression of AKs makes it unlikely that the assumption of constant risk is accurate. Second, Dodson assumed that each subject had the mean number of AKs for the overall sample. The Nambour findings of the highly skewed distribution of AKs in the population,83 calls this assumption into question.

Despite these limitations, Dodson’s point—that a 1-year time frame makes the progression rate seem less significant clinically than it actually is—is well-taken. While a rate of 24 per 10,000 per year sounds low, it is similar to the annual risks associated with many conditions that we treat routinely. For example, the annual risk that a patient who has a 0.5 cm. colonic polyp will develop carcinoma is roughly of the same magnitude.

Higher rates of progression were observed in the SKICAP-AK study, a large, controlled trial of retinol supplementation conducted in Arizona.60 In the placebo arm of that trial, 12 percent of 1,140 patients who had 10 or more AKs at baseline and no prior history of skin cancer developed an SCC within 5 years. Cumulative incidence rates of SCC were even higher (21–36 percent) among subjects who had a history of prior skin cancer.

Are the high rates of progression in the SKICAP-AK trial consistent with the frequently cited rate of approximately 1 per 1000 per year? To answer this question, we constructed Table 4, which extends the observations Dodson6 used in his analysis of 10-year rates of progression.1, 59 The first three columns of data replicate Dodson’s analysis, except that we calculated 5-year progression rates instead of 10-year rates. The average number of AKs per patient is assumed to be 7.7, the same as it was in Marks’ original study. The fourth column of data indicate the cumulative 5-year rates of progression to SCC if the yearly rate of progression for a single AK is 1 per 1,000 (0.1 percent). At this rate, over 5 years 3.8 percent of patients, or 1 in every 26, would develop a new SCC.

Table 4 Hypothetical rate of progression over 10 and 5 years

| 1st Marks study | 2nd Marks Study | Dodson | Base rate of 1 per 1000 | Moon study (hypothetical)
Yearly rate of progression | 0.24% | 0.08% | 0.14% | 0.10% | 0.10%
Average number of AKs per patient | 7.7 | 7.7 | 7.7 | 7.7 | 25
Not transform | 99.8% | 99.9% | 99.9% | 99.9% | 99.9%
None transform in 1 year | 98.2% | 99.4% | 98.9% | 99.2% | 97.5%
At least 1 transform in 1 year | 1.8% | 0.6% | 1.1% | 0.8% | 2.5%
none transform in 10 years | 83.1% | 94.4% | 89.8% | 92.6% | 77.9%
at least 1 transform in 10 years | 16.9% | 5.6% | 10.2% | 7.4% | 22.1%
none transform in 10 years | 91.2% | 97.2% | 94.7% | 96.2% | 88.2%
At least 1 transform in 5 years | 8.8% | 2.8% | 5.3% | 3.8% | 11.8%
NNT in 1 year | 417 | 1333 | 714 | 1000 | 1000
NNT in 5 years | 11 | 35 | 19 | 26 | 9

NNT=number needed to treat. This is the minimum number of AKs that would have to be destroyed to prevent 1 cancer in the specified number of years of followup.

We then applied these assumptions to the Moon study, asking the question, How many AKs per patient would there have to be for the 5-year rate of developing a new SCC to be 12 percent (the rate observed in patients who did not have a history of a previous SCC)? As shown in the table, if the average number of AKs per patient was 25, the observed rate in the Moon study would be consistent with an average yearly rate of progression of 1 per 1,000 AKs. In fact, if the progression rate from the first Marks study (2.4 per 1,000) were used, the cumulative 5-year incidence of SCC would be 12 percent if the average patient had only 11 AKs (not shown). Moon’s sample included only those patients who had 10 or more AKs. Because the distribution of AKs is highly skewed, with a small proportion of patients having most of the lesions, it is very plausible that the average number of AKs per patient in Moon’s sample was this high.

These estimates do not address whether treating the AKs initially has any impact on the rate of developing SCC in the long run. Given the dynamic nature of AKs, and the high incidence of new lesions in patients who are prone to develop them, the risk of progression to SCC may be significant even in patients undergoing regular treatment. No studies compare observation alone, or promotion of sunscreen use and sun avoidance with selective removal of lesions, to aggressive treatment to remove AKs. Under these circumstances, the impact of a single treatment on 5-year or 10-year outcomes cannot be estimated meaningfully. Other critical issues are whether it is possible to focus on patients or lesions at higher risk of developing SCC; and whether there is sufficient evidence to conclude that an equivalent benefit can be achieved by monitoring patients, with selective removal of lesions that develop characteristics suggestive of progression. These issues are addressed in subsequent sections of this report.

Other studies have been cited as evidence about the rate of progression to SCC, but these studies have serious methodologic flaws. A recent summary by Glogau cites three additional articles that reported the percentage of AKs progressing to SCC.87 Of these three, two are unpublished manuscripts.15, 88 One of the unpublished manuscripts15 had no data about progression of AKs to SCC. The other unpublished manuscript88 is a brief report of the results of a followup study of a series of 106 white adults in North Carolina who were diagnosed with AK. Of the 106, 26 (25 percent) were lost to followup. Of the remaining 80 patients, 36 (45 percent) had a history of skin cancer before entry into the study. Initially, 116 AKs were biopsied in these 80 patients. Over a median followup period of 39 months, 23 of the 80 patients (29 percent) developed at least one SCC. The SCCs had roughly the same distribution by body site as the original AKs. Methodologically, the study had serious flaws. The report does not describe how subjects for the study were selected, the reasons for dropouts, or how the AKs were treated. It is unclear whether lesions were biopsied for the purpose of the study, or whether they represent a subgroup of a larger group of patients and AKs selected for biopsy because their lesions had suspicious characteristics. It is also unclear whether these patients underwent destructive therapy for their AKs initially and what monitoring or therapy they underwent during the study period. If the AKs were treated initially and the patients did not undergo any subsequent followup for a median of 39 months, the study indicates that, especially in patients with a history of skin cancer, destruction of AKs does not provide protection against the subsequent development of SCC over 3 years. Because the study is uncontrolled, it is not clear whether the initial treatment was partially effective. Finally, the study provides no information on the likelihood that a particular AK will progress to SCC.

A third study cited in Glogau, published in 1976, reported that 12 percent of patients with AK develop “actinic keratosis with squamous cell carcinoma,” which is described by the author as “a nonaggressive lesion” that should be classified as “a separate entity distinct from malignant squamous cell skin and mucocutaneous tumors, which do metastasize.”89 The article does not describe the sample size or design of the study that is the source of this estimate, but it is likely to be an earlier series based on specimens referred for to a pathology laboratory.90 The article provides no information about the likelihood that AK will progress to “malignant” squamous cell carcinoma. The main point of the article is that patients who have “actinic keratosis with squamous cell carcinoma” are at high risk for developing internal or extracutaneous cancers and often die of them.

## Key Question 3 Will reducing the incidence of SCC reduce morbidity and mortality?

The rationale for treating asymptomatic AKs is to prevent morbidity and mortality from SCC. Implicit in this rationale are the assumptions that SCC arising in AKs can cause significant morbidity and mortality, and that treatment of AKs would be more effective in preventing these consequences than treatment of SCC after it develops.

SCC can cause morbidity by invading deep structures of the skin (requiring extensive surgery), by recurring, and by metastasizing to local lymph nodes and distant organs. How often does SCC lead to these complications? In 25 studies over 6 decades, the incidence of metastases in SCC varied from 0.5–16 percent.91 A review article, published in 1992, combined results from over 70 surgical and dermatologic case series, and estimated that 2.3 percent of SCCs in sun-exposed areas metastasized by 5 years, and 5.2 percent in series following patients for longer than 5 years.11 Unfortunately, the methodology used in the studies on which these estimates were based was not considered in the review. Historically, the lack of registry data has made it difficult to measure the probability that an SCC will metastasize, or the time it takes to do so. In the 1960s, two studies originating in dermatology practices found low rates of metastasis for SCCs that did not originate on the lip, ear, or eye, or in scars.10, 92 The authors of both these studies wisely noted that referral bias was the probable explanation of the wide variation in reported rates of metastasis: patients with more extensive disease might be referred to surgeons or radiotherapists rather than to dermatologists. Other factors, including the efficacy of surgical procedures and prior exposure to ionizing radiation given as treatment for benign head and neck conditions—as well as the prevalence of arsenic poisoning, hematologic disorders, and immune compromise—might also cause results among studies done over several decades to differ.

Case reports and case series have demonstrated that squamous cell cancers that appear histologically to originate in AKs can metastasize.3, 93 Data from clinical studies about the frequency with which this occurs conflict. An article by Lund published in 1965 is frequently cited to support the view that SCC arising in AK rarely metastasizes.92 Lund’s report, which was intended to provide a rough estimate of the frequency of metastasis, was not rigorous methodologically; it used an unreliable sampling methodology and relied heavily on extrapolation. The main strength of the study was that it attempted to sample SCCs that were encountered in community dermatologic practice. Lund sent a questionnaire to 45 dermatologists who sent skin biopsies to a pathology department in North Carolina. The dermatologists identified 17 cases of metastatic SCC from their practices. Lund also reviewed 1,000 skin biopsies. Of these, 82 revealed squamous cell tumors, 17 of which were clearly invasive. Based on this information, he estimated that one of every 200 clearly invasive squamous cell cancers metastasized. In a more detailed review, Lund concluded that, based on histology and clinical histories, only five of 12 cases of metastatic squamous cell cancers originated from actinic keratosis, and of these, two originated on the ear. Because this proportion is lower than the proportion of SCC that originates in AKs, Lund concluded that metastasis occurs in far fewer than one in 200 cases of SCC originating from an AK (excluding those on the ear or lip).

In 1968, Epstein and colleagues estimated the frequency of metastasis using data from the California Tumor Registry, which included 6,900 squamous cell carcinomas of the skin diagnosed at 38 hospitals during the period 1942–1962.^22^ Of these, 142 (2 percent) had metastasized to lymph nodes or distant organs by the time they were entered into the registry. The registry did not contain information about whether the tumors originated in AKs. Noting that nearly 70 percent of these occurred on the exposed areas of the body, Epstein and colleagues concluded that “one should not ignore the possibility of metastatic extension in malignancies presumably of solar causation.” The main weakness of the study was that cases of SCC diagnosed in the hospital may not be representative of SCC generally.

An Australian study published in 1986 confirmed Epstein’s report.48 A series of 299 consecutive patients with SCC were identified from the records of a private pathology service. The referring physicians of 291 of the 299 patients responded to a questionnaire. Of 241 tumors that occurred on sun-exposed areas of the skin, 1.6 percent (4) had metastasized, and 7.5 percent (18) had recurred locally. In the subset of these patients who had been followed for 2 years or more, 2.1 percent had metastasized, and 7.4 percent had recurred locally. As expected, rates of metastases after 2 years or more of followup were higher for cancers that occurred on the lip (4 percent) and on non-sun-exposed areas (12.5 percent).

## Key Question 4 Are there characteristics of actinic keratoses that can be used to identify lesions that are more likely to progress to invasive squamous cell carcinoma?

As stated earlier, AKs on the lip, ear, or eye are associated with a high risk of developing metastatic SCC. AKs in these locations were excluded from our analysis.

Some characteristics of lesions are commonly cited as signs that an AK is more likely to progress. These features are induration, erythema, bleeding, palpability, erosions, pain, hyperkeratosis, or increasing diameter. These characteristics may be indicators that a lesion has already progressed to SCC, but we found no studies of the probability of SCC when these features are present or absent. The diagnosis of AK is usually made clinically, but lesions that have these characteristics are not diagnosed clinically to be AK; they are biopsied. We found no prospective studies that measured the ability of characteristics of AK to predict progression to SCC.

## Key Question 5a Are there characteristics that can be used to identify a group of patients at higher risk of progression to invasive squamous cell carcinoma?

In addressing this question, we excluded immunocompromised patients, such as transplant patients, those with myelodysplasia, and those undergoing chemotherapy.

In other patients, several good-quality epidemiologic studies indicate that age,20, 28, 83, 94–98 sex,20, 28, 83, 94–98 skin type,20, 28, 94 and various measures of sun exposure20, 28, 94, 97–101 are risk factors for the development of both AK and SCC.

Good-quality epidemiologic studies clearly show that the number of AKs or the presence of AKs is a strong predictor of SCC. An Australian study,98 the Nambour Trial, examined 2,095 people and then surveyed 1,770 of them 2 years later (response rate 84.5 percent) about any skin cancers treated by a doctor over the ensuing 2 years. Treating doctors were contacted to confirm the diagnosis. The number of AKs was more strongly associated with the development of SCC than was any other factor. The relative risk of SCC rose with the number of AK on the face. Adjusting for age and sex, for 1–5 AKs, the relative risk of SCC was 1.7 (0.4–6.5); for 6–20 AKs, the adjusted relative risk was 4.2 (1.1–16.1); and for more than 20 facial AKs, the adjusted relative risk was 11.0 (2.6–46.6). Other clinical signs of actinic damage, such as solar lentiges on the hands, telangiectasia of the face, and actinic elastosis of the neck, were also associated with a higher risk of both AK and SCC.28

A case-control study, also from Australia,100 of people with and without SCC found that of all of the cutaneous indicators of solar damage measured, only the number of AKs had a stronger relationship with SCC than with BCC. A cross-sectional study in Maryborough, Australia95 examined 2,113 patients over 1 week for the presence of skin cancer and AK. SCC occurred more frequently in people with AK, but the difference was not significant.

The presence of AK is a marker for the risk factors that predict SCC and is itself a powerful predictor for the development of SCC. Therefore, only studies that control for, or stratify by, the presence of AK, provide information about the existence of a high-risk group among patients who already have AK. Among patients who have AKs, what factors are associated with a high risk of developing SCC?

One cross-sectional study102 of 6,416 Australians examined risk factors for (prevalent) SCCs while controlling for AK. AKs were present on 2,643 people (41 percent), and 38 (0.6 percent) had an SCC. The presence or absence of an AK was the strongest predictor of SCC. Only one of the 38 patients with an SCC did not have a coexisting AK, and this patient was severely ill and had a history of several long courses of corticosteroids.

In a logistic regression analysis, the best combination of variables for predicting SCC was the presence or absence of an AK, age, sex, and burning exposure. None of the other variables considered in the logistic regression were significant after these were taken into account. Unfortunately, the investigators did not use the number of AKs or a history of SCC as potential risk factors. A formula based on this logistic regression illustrates the impact of several risk factors associated with SCC. Based on the formula, the probability of finding a SCC ranged from 0.12–5.71 percent. For example, a 40-year-old woman with a low propensity to sunburn has a probability of 0.12 percent of developing SCC, a 60-year old man with a moderate propensity to sunburn has a probability of 1.6 percent and a 70-year-old man who sunburns very easily has a 5.71 percent probability.

One large, good-quality prospective study,60 discussed earlier, provides the best evidence about risk factors for SCC within a sample of patients with AKs. The subjects in this study were participants in the SKICAP-AK randomized trial of retinol to prevent skin cancer. All were Arizona residents whose median age was 63 (range 40 to 84) and who had, at least, 11 AKs and, at most, two prior confirmed squamous cell carcinomas or basal cell carcinomas (BCC). After 5 years, 249 subjects (10.8 percent) had developed a new SCC. The strongest risk factor for developing SCC was a prior history of skin cancer. Nineteen percent (445/2,297) of the subjects had a prior skin cancer (numbers of prior basal and squamous cell cancers were not reported separately). In the placebo group, the risk of developing SCC for persons with no prior skin cancer was 0.12; for those with one prior skin cancer it was 0.21, and for those with two or more prior skin cancers, it was 0.36. Similarly, in the intervention group, the probabilities were 0.09, 0.12, and 0.24 for those with none, one, and two or more prior skin cancers, respectively. Other risk factors that predicted the development of SCC were male sex, age over 63 years, eight or more moles and freckles, skin that burns easily, and hours of sun exposure per week (0.16 for >10 hours vs. 0.12 for 0–10 hours). None of these factors was as strongly predictive as a prior history of skin cancer. If the average patient in this study had 15 to 25 AKs (see Table 4), the high rates of developing SCC in patients with a prior history of skin cancer are consistent with a yearly rate of progression for a single AK of 3–6 per 1,000.

In the context of these results, an important finding of the Nambour study83 was that a small percentage of individuals with AKs had a major proportion of the burden of illness. Among the men in the study, nine of the 47 subjects (about 20 percent) had 73 percent of the AKs. Four of the 46 women (9 percent) had 67 percent of the AKs. This concentration of the burden of illness suggests that the risk of developing SCC is highly concentrated in patients with multiple AKs.

## Key Question 5b Are there data to support a monitoring protocol that will allow detection and treatment of any squamous cell carcinoma at a sufficiently early stage?

There are no studies of the results of monitoring patients with AK to detect and treat SCC when it arises. The safety of such a strategy has been inferred from the results of the prospective studies of observation listed in Table 3. Of these, the two studies by Marks and colleagues were the only ones in which any patients developed SCCs. Followup of the patients who developed SCC might have provided information on whether all of them were cured by initial treatment, but the authors did not report any followup results.

The study by Frost was a randomized trial of two different frequencies of followup visits for patients with AK. The number of new and persistent AKs was carefully measured every 6 months for 18 months in 1 group and every 2 months for 14 months in the other group.83 The study was small (n=94) and no SCCs occurred during the trial.

A few other studies provide scant, indirect information about monitoring. A 32-month followup of eight patients who underwent 5-FU or chemical peel found that, 6 months after treatment, the number of AKs per patient was approximately one-fourth to one-fifth the number present before treatment (18 initially vs. three after 6 months for 5-FU, 20 initially vs. five after 6 months for peel).73 After 32 months, patients had 10 AKs (in the 5-FU group) and 15 AKs (in the peel group).

A monitoring strategy assumes that metastasis or deep local invasion does not develop immediately after progression from AK to SCC. Conversely, one rationale that has been given for aggressive treatment of AKs is that SCC may metastasize early in its course, making a strategy of monitoring ineffective. Very little evidence supports either side of this issue. Only one study, the California Tumor Registry study discussed earlier,22 attempted to examine whether delay in treatment was related to the likelihood of metastasis. In that series of cases of metastatic SCC, the authors reported that, between the time a lesion was first noted by the patient and the time the patient was entered into the registry (the time of diagnosis), the median delay was 9.4 months. Three (2.5 percent) of the 119 metastatic tumors had a delay time less than a month. Another 42 (35.3 percent) had a delay of 1 to 6 months; 36 (30.2 percent) had a delay of 7–12 months; 13 (11 percent) had a delay of 13–24 months, and 25 (21 percent) had a delay of more than 2 years. The reliability of this information is difficult to assess, because the report did not say whether the delay was assessed by the patient’s self-report or by review of the medical record.

## Key Question 5c For patients who have multiple, recurrent actinic keratoses, does the effectiveness of different management strategies differ?

We examined the effectiveness of immediate treatment of all AKs versus selective treatment of some AKs and monitoring for others, followed by selective treatment of those that persist, enlarge, or become suspected squamous cell cancers. By “effectiveness” we mean the impact on death, disfigurement, and major surgical procedures due to SCC, as well as the frequency and severity of complications of treatment.

Available data are insufficient to determine whether these strategies result in different outcomes. There are no data on the relative effects of immediate treatment of all AKs and selective treatment of some AKs on morbidity or mortality from SCC. In those studies of treatment of AKs that follow patients long enough for some SCCs to develop, it is not clear what strategies were used during the followup period. The effects of the initial treatment cannot be distinguished by the effects of subsequent management because these are not adequately described.

Because a monitoring strategy might employ fewer treatments less often, it might result in lower short-term morbidity from the side effects of treatments, but this has not been studied directly. Moreover, as discussed earlier, patients seen in dermatologic practice may represent a subset of AK patients who are more motivated than others to have lesions removed or controlled; if this is the case, the utility of lower morbidity from treatment might be counterbalanced by the disutility of living with more lesions. Data about patient preferences for treatment versus no treatment are inadequate to assess this tradeoff.

## Results of Additional Analysis of Medicare Claims Data

As mentioned in the Methods section, we conducted an analysis using the Medicare 5-percent Sample Standard Analytical File Part B to assess the usefulness of the data to obtain information about AK and SCC. For the period of 1991 through the first half of 2000, we found 4.35 million Medicare beneficiaries who had a malignant skin neoplasia diagnosis and a procedure to remove a possible squamous cell carcinoma (the average annual number of Medicare beneficiaries aged 65 or older during this period was 31.57 million). Of these, 2.82 million, or 64.7 percent, had a previous actinic keratosis diagnosis. Most of these, 2.33 million, or 82.5 percent, also had a removal procedure for actinic keratosis. More than one-third (35.3 percent) of the beneficiaries we found with a malignant skin neoplasia diagnosis and removal procedure did not have a previous diagnosis of actinic keratosis.

One caveat of this analysis is that the ICD-9-CM diagnosis code for malignant skin neoplasia (173.x) does not distinguish between squamous and basal cell carcinoma. Data external to the Medicare system on the ratio of squamous and basal cell carcinomas could be used to estimate prevalence of squamous cell carcinoma in the Medicare population. Another issue is the possible overestimation of beneficiaries with malignant skin neoplasia without a previous actinic keratosis diagnosis. It is possible that an individual became eligible for Medicare after a diagnosis of actinic keratosis but before progression to squamous cell carcinoma. In such a scenario, we would not have captured their actinic keratosis diagnosis within the Medicare claims system.