# Methods

## Literature Search Strategy

We searched the topic of actinic keratosis in the MEDLINE database from 1966 to January 2001, and in the Cochrane Controlled Trials Registry, using the search terms actinic keratosis, squamous cell carcinoma, and precancerous lesions. We also searched an Endnotes library compiled for a recently completed assessment of skin cancer screening.54 To identify additional relevant articles, we examined the reference lists of several review articles. In some cases we contacted experts, usually authors of cited unpublished manuscripts, to identify additional articles.

Working in pairs, the investigators reviewed abstracts and titles returned in the MEDLINE search. Titles and abstracts from the Cochrane Controlled Trials Registry that were not also retrieved from MEDLINE were reviewed by one of the authors (MH). We retrieved and read the full-text articles of 183 titles and abstracts that were judged relevant to one of the key questions. We also retrieved 90 articles identified by reference lists, the skin cancer screening library, experts, and authors. Studies were included if they contained original data relevant to one of the key questions. Of 45 included studies, 23 addressed the treatment of AK, five addressed the incidence, progression, and regression of AK, three addressed the risk of metastasis, four addressed the accuracy of diagnosis of AK or SCC, and 10 addressed risk factors for AK or SCC. We reviewed and abstracted 23 articles on the efficacy of various modalities in the treatment of actinic keratoses. Three of these studies,55–57 concerning pyruvic acid, topical colchicine, and Er:YAG laser, are not discussed further because they are not commonly used therapies.

## Data Extraction and Synthesis

We abstracted information about the patient populations, interventions (when applicable), outcome measures, and characteristics of the study design from these 45 articles. We used criteria developed by the US Preventive Services Task Force (USPSTF)58 to summarize information about the quality of included controlled trials of AK treatments and observational studies of the natural or treated history of AK and of risk factors for SCC. We used these criteria to classify articles as good, fair, or poor for their study design category (for example, controlled trial or cohort study) (Appendix 2).

Information about included prospective studies of AK incidence and progression, and about studies of various treatments for AK, was used to construct evidence tables. In addition, we constructed a simple mathematical model to synthesize information from studies of progression of AK to SCC and from one study of risk factors for SCC. The purpose of this analysis was to determine whether results of a previous model,6 based on the results of two prospective studies,1, 59 were consistent with the results of a more recent prospective study60.

## Analysis of Medicare data

We conducted an analysis to supplement published data about the prevalence and consequences of AKs in the Medicare population and to assess the usefulness of the data to obtain information about AKs and squamous cell cancer of the skin. The data source for this analysis was the Medicare 5-percent Sample Standard Analytical File (SAF) Part B from years 1991 through 2000 (first half).

Finder files were created using the Health Insurance Claim number (HIC), a unique beneficiary identification number. All beneficiaries with claims having any one of the HCFA Common Procedure Coding System (HCPCS) codes listed in Appendix 3, Table 1, were included in the finder files. Each beneficiary represented in the finder files was one that possibly had a removal procedure for a squamous cell carcinoma or actinic keratosis. The finder files were then used to retrieve all claims from each beneficiary.

We identified claims with an ICD-9-CM diagnosis code for actinic keratosis (702.0) or malignant skin neoplasia (173.x). Among these claims, we identified beneficiaries who had a relevant removal procedure (Appendix 3, Table 2) and a malignant skin neoplasia diagnosis. We determined whether or not these beneficiaries had an actinic keratosis diagnosis prior to the date of removal of the cancer. Among beneficiaries who had a previous diagnosis of AK, we determined whether an actinic keratosis removal procedure had been done. Results of the analyses were weighted to represent population estimates for Medicare beneficiaries 65 years of age or older.

Table 2 Efficacy of treatment for actinic keratoses

Treatment | Study design (Author, Year) | Design features | Patients | Baseline risk factors | Treatments | Co-interventions
| | | | | | | [underlined: 3–4 months]
5-FU | Controlled trials Bercovitch, 1987 | Randomized to arm, double-blinded | Convenience sample of 20 patients, probably from a referral clinic | 15 AKs per arm, 8 of 20 had a history of SCC | 5-FU vs. 5-FU plus tretinoin | Not specified | Reduced AKs per patient from 15.3 to 4.2
5-FU | Kurwa, 1999 | Randomized to hand, not blinded | Convenience sample of 17 patients from a referral clinic | Long history of AKs | 5-FU vs. PDT | Not specified | 70% reduction in mean lesional area
5-FU | Lawrence, 1995 | Not randomized, face, not blinded | Convenience sample of 15 patients, probably from a referral clinic | 15 AKs on each side of face | 5-FU vs. peel | Additional treatments throughout the study period | Reduced AKs per patient from 15.3 to 3
5-FU | Witheiler, 1997 | Not randomized, face, not blinded | Followup of 8 available patients from Lawrence study | 18 AKs on each side of the face | 5-FU vs. peel | Additional treatments given at 1 and 6 months | N/A
5-FU | Simmonds, 1973 | Not randomized, face, double-blinded | Convenience sample of 16 patients from private clinic | Presence of AKs on face | 5-FU 1% vs 5% | Not specified | Patients at < 1 mo. Judged to have equal treatment effects to each side of face
5-FU | Case series Simmonds, 1972 | Face, scalp, hands | Series of 134 patients from a referral clinic | Not stated | 1% 5-FU BID | Not specified | N/A
5-FU | Pearlman, 1991 | Face | Convenience sample of 11 patients, probably from a referral clinic | 20+ AKs on face | Pulse 5FU BID 1–2 days per week for up to 9 weeks (AV 6.7wks). | Not specified | 98% reduct at end of rx (max 9 weeks)
Tretinoin | Controlled trials Alirezai, 1994 | Randomized, double-blinded | Multicenter study of 100 patients, France | 9.2 AKs on face, 8.1 on scalp, 5.9 on arm | Tretinoin vs. vehicle cream | Not specified | Face: 65% in tretonion group had 30–100% clearance compared with 45% in placebo group
Tretinoin | Bercovitch, 1987 | Randomized to arm, double-blinded | Convenience sample of 20 patients, probably from a referral clinic | 15 AKs per arm, 8 of 20 had a history of SCC | 5-FU vs. 5-FU plus tretinoin | Not specified | Reduced AKs per patient from 15.7 to 3.4
Tretinoin | Misiewicz, 1991 | Randomized to face, double-blinded | Convenience sample of 26 patients, from a referral clinic | 8 AKs per side of face | RO 9706 vs tretinoin | Not specified | Reduced AKs per patient from 8 to <6 at 4 months
Cryotherapy | Case series Lubritz, 1982 | Retrospective review, lesion focused treatment | Convenience sample of 70 patients with a total of 1018 AKs | Most patients with obvious actinic-damaged skin | Cryotherapy | Not specified | N/A
Peels | Controlled trials Lawrence, 1995 | Not randomized, face, not blinded | Convenience sample of 15 patients, probably from a referral clinic | 15 AKs on each side of face | 5-FU vs. medium depth peel | Additional treatments throughout the study period | Reduced AKs per patient from 16 to 3
Peels | Witheiler, 1997 | Not randomized, face, not blinded | Followup of 8 available patients from Lawrence study | 20 AKs on each side of the face | 5-FU vs. medium depth peel | Additional treatments given at 1 and 6 months | N/A
Peels | Marrero, 1998 | Randomized to side of face, not blinded | Convenience sample of 18 patients, probably from a referral clinic | 13–14 AKs on each side of face | 8 weekly treatments with glycolic acid+5FU vs. glycolic acid alone (superficial peel) | Not specified | N/A
Peels | Tse, 1996 | Not randomized, face, not blinded | Convenience sample of 13 male patients at 2 referral clinics | Not stated | Glycolic Acid plus TCA peel vs Jessners plus TCA peel | 2 weeks of pretreatment with nightly tretonoin | At 2 months, "clinical response score" for GA+TCA was fair-good, versus, fair for TCA+Jessner's
Peels | Chiarello, 2000 | Face, scalp, arms, hands | Convenience sample of 373 patients from a private clinic | Extensive AKs | Cryopeeling (extensive cryosurgery) | Retin-A and sun protection after treatment | N/A
Dermabrasion | Case series Coleman, 1996 | Face, head and scalp, nose, or upper lip | 23 patients from 2(?) referral clinics, Florida | "chronic recalcitrant AKs who failed other treatments | | No (personal communication, author) | N/A
Photodynamic therapy | Controlled trial Ormrod, 2000 | Randomized on face, scalp, double-blinded | Sample of 243 patients in 2 multicentered trials | 4–15 AKs per patients | Placebo vs. 20% ALA solution | Not specified | 88% of patients had >= 75% reduction in AKs at 12 weeks
Photodynamic therapy | Kurwa, 1999 | Randomized to hand, not blinded | Convenience sample of 17 patients from a referral clinic | Long history of AKs | 5-FU vs. PDT | Not specified | 70% reduction in mean lesional area
Photodynamic therapy | Jeffes, 1997 | Face, scalp, trunk, and extremities | Pilot study of 40 patients from a referral clinic | 6 AKs per patient | Placebo vs. 20% or 30% ALA | Not specified | Overall, 50% of AKs had a complete response, vs. 3% with placebo. 91% of AKs on face or scalp had CR (45% on trunk and extremities).

Treatment | Study design (Author, Year) | Efficacy | | Adverse Effects | Study Quality (reasons)
| | [underlined: 6–11 months] | [underlined: 1 year or more]
5-FU | Controlled trials Bercovitch, 1987 | N/A | N/A | Not specified | Good
5-FU | Kurwa, 1999 | N/A | N/A | 11/14 filled out "adverse effects". No dif b/t PDT and 5-FU | Good minus (4)
5-FU | Lawrence, 1995 | Reduced AKs to 2 | Reduced AKs to 2 by 1 year. | 2 pts had impetiginized eczematous rxn. Chem Peel in 9/15 pts was "preferred rx". | Fair Minus (1, 3)
5-FU | Witheiler, 1997 | N/A | At 32 months, 5-FU reduced mean number of AKs from 18 before treatment to 10. | Not specified | Fair Minus (1, 3)
5-FU | Simmonds, 1973 | N/A | N/A | Not specified | Fair
5-FU | Case series Simmonds, 1972 | N/A | At 24 months 25% of one cohort, and 40% of another, required retreatment. | Not specified | Fair (5)
5-FU | Pearlman, 1991 | At 9mo first 6 pts to reach this marker had 86% clearing. | N/A | Minimal, none with swelling, oozing or ulceration. | Fair
Tretinoin | Controlled trials Alirezai, 1994 | N/A | N/A | mod-severe 68% rx vs 24% placebo by authors | Good Minus (2)
Tretinoin | Bercovitch, 1987 | N/A | N/A | Not specified | Good
Tretinoin | Misiewicz, 1991 | N/A | N/A | Not specified | Good minus (4)
Cryotherapy | Case series Lubritz, 1982 | N/A | Patients evaluated from 1–8.5 years after initial treatment with 12/1018 recurrences of AKs | Not specified | Fair (retrospective, 3)
Peels | Controlled trials Lawrence, 1995 | Reduced AKs to 3 | Reduced AKs to 2 by 1 year. | Erythema for 3 mo in 1 patient. Chem Peel in 9/15 pts was "preferred rx". | Fair Minus (1, 3)
Peels | Witheiler, 1997 | N/A | At 32 months, TCA reduced the mean number of AKs from 20 before treatment to 10. | Not specified | Fair Minus (1, 3)
Peels | Marrero, 1998 | 5FU+glycolic acid reduced AKs, from 13 to 0.9; glycolic acid alone reduced AKs from 13.7 to 11.6. | N/A | Not specified | Good
Peels | Tse, 1996 | N/A | N/A | Not specified | Fair (1)
Peels | Chiarello, 2000 | At 6 mos. 336/373 with 4% recurrence rate (rr) At 6–12 mos. 167/373 with 9% rr | At 12–18 mos.,124/373 with 12% rr At 18–24 mos., 92/373 with 16% rr At 24–30 mos., 71/373 with 22% rr At 30–36 mos., 64/373 with 22% rr At 36–42 mos., 50/373 with 40% rr | Not specified | Fair (2)
Dermabrasion | Case series Coleman, 1996 | N/A | At 1 yr, 22/23 with no AK (96%), at 2 yr 19/23 no AK's (83%), at 3 yrs 15/19 available had no AKs (64%) 13/23 at 5 yrs 7/13 with no AK(54%). No SCCs were found (5 BCCs seen after 4 yrs.) | Not specified | Fair Minus (2)
Photodynamic therapy | Controlled trial Ormrod, 2000 | N/A | N/A | Erythema, scaling in most patients. | Good
Photodynamic therapy | Kurwa, 1999 | N/A | N/A | 11/14 filled out "adverse effects". No dif b/t PDT and 5-FU | Good
Photodynamic therapy | Jeffes, 1997 | N/A | N/A | "Minimal" | Fair (1, 4)

Notes. (1) Treatment not randomized to side of face, or uncertain whether randomization was used. (2) Low or uncertain followup rates. (3) unequal co-interventions in compared groups (4) assessment not masked or other problem with masking (5) no mention of number of lesions or standard for retreatment