# Introduction

Squamous cell cancer of the skin (SCC) has the potential to metastasize and may account for up to 20 percent of deaths from skin cancer. In epidemiologic and pathologic studies, actinic keratoses (AKs), also known as solar keratoses or senile keratoses, are the precursors of at least 60 percent of squamous cell cancers.1–3 AKs occur most frequently in the elderly, especially elderly men, who are also at highest risk for death or disfigurement from squamous cell cancer. Some experts argue that, because AKs are precancerous lesions, all of them should be removed immediately to prevent these complications of squamous cell cancer.4–7 An alternative approach is to monitor patients who have multiple, recurrent AKs, removing only those lesions that persist, enlarge, or develop characteristics that suggest squamous cell cancer.8

In this paper, we examine evidence for the assumptions about the natural history and effectiveness of treatment that underlie different strategies for the management of AKs. Our assessment focuses on the choice of treatment for asymptomatic AKs in normal hosts, excluding those on the lip, ear, or eye. There is consensus that all AKs on the lip, ear, or eyelid should be removed surgically, because SCCs at these sites have a high rate of metastases.9–11 For the same reason, there is also consensus that AKs should be removed routinely in immunocompromised patients, such as transplant patients,12 patients with myelodysplasia, and patients undergoing chemotherapy, as well as patients with a history of multiple nonmelanoma skin cancers.

We specify “asymptomatic” patients because, in many cases, AKs are treated for reasons other than preventing progression to cancer. AKs may be painful or pruritic, or may have an adverse affect on appearance. As Marks, the most notable advocate of a conservative approach to managing AKs, wrote:

…the question (is) whether or not treatment is justified in the prevention of morbidity and mortality due to squamous cell carcinoma. This discussion needs to be kept on that focus. It is not about whether or not AKs should be treated on the basis of symptoms, cosmetic appearance, or recent change, or merely because the patient does not want to have an abnormality. The treatment of AKs under these circumstances is justified and is part of overall patient care, not for preventing problems due to SCC.8

## Burden of Illness and Epidemiology

Actinic keratoses. Destruction of AKs is the single most commonly performed dermatologic procedure in the outpatient setting.13 In an analysis of data from the National Ambulatory Medical Care Survey, in 1993 and 1994 there were 3.7 million office visits and about 5.2 million procedures for actinic keratoses, more than 3 times the total for squamous cell cancer, basal cell cancer, and melanoma combined.14 In an analysis of 1 year of claims from a Medicare HMO in Florida, 13,108 episodes of treatment for AK were recorded among 11,800 beneficiaries; there were approximately 10 times as many visits for AK than for squamous cell cancer and basal cell cancer combined.15 Our own analysis of Medicare data found that, nationally, between 1 in 11 and 1 in 15 beneficiaries over 65 years of age were treated for AKs in the years 1991 to 1995.

Impressive as these numbers are, only a small proportion of individuals with AKs seek or receive treatment. In parts of Australia and the southern part of the United States, the lifetime risk of developing an AK is higher than 50 percent, and may reach 90 percent among those who live to be 80 years or older.16, 17 In a good-quality, population-based survey of 978 white adults in 643 rural Tennessee households, 26.5 percent of men and 10.2 percent of women had at least one AK.18 Among men 65–74 years of age, 51.5 percent had an AK; among men 75 years or older, 63.6 percent did. A smaller survey in Texas found that 30 percent of paraquat workers and their unexposed friends had at least one AK.19

The prevalence of AK is lower in certain northern latitudes. For example, in a good-quality casefinding survey conducted in northwest England, the prevalence of AK in persons 70 years or older was 15.4 percent in men and 5.9 percent in women.20 The prevalence in a Welsh study was 23 percent among 1,023 persons 60 years or older.21

Little has been published about the reasons patients seek care for AKs. In some epidemiologic studies, low rates of compliance with referrals for treatment of AK or SCC have been attributed to cultural attitudes that minimize the importance of these lesions and attribute them to “normal” aging.18, 20 In one series of cases of metastatic SCC, one of every five patients had delayed more than 2 years before seeking care for a skin lesion.22 Unfortunately, no study has explored how attitudes differ between those who seek timely treatment and those who do not.

Squamous cell carcinoma. Squamous cell carcinoma of the skin accounts for less than 0.1 percent of all cancer deaths. However, squamous cell cancer has the potential to metastasize and may account for up to 34 percent of deaths from skin cancer among persons 65 through 84 years of age, and 56 percent of deaths from skin cancer among persons 85 years and older.23 A Finnish study of 2,927 individuals diagnosed to have SCC reported survival rates relative to that of the age-matched general population. Five-year survival was 87.7 percent of that of the general population in men and 84 percent of that in women; the relative survival rate ranged from 73.2 percent to 97.2 percent, depending on sex and the site of the cancer.24 In contrast, survival rates for individuals diagnosed to have basal cell carcinoma were indistinguishable from those of the general population. These figures might reflect excess mortality from SCC, excess mortality from other diseases for which SCC is a marker, or both.

Most studies of the natural history of squamous cell cancer of the skin have been done in selected patients who have an elevated risk due to environmental exposures, such as UV–A radiation for psoriasis.25, 26 Patients with these exposures may constitute a substantial proportion of all patients who die of metastatic squamous cell cancer.27 Elderly men are also over-represented among patients who die of squamous cell cancer. While there is strong suspicion on clinical grounds that advanced locally invasive or metastatic nonmelanoma skin cancers results from medical neglect, careful studies of the rate of progress of SCCs and the consequences of delay are lacking.

In Queensland, Australia, a good-quality epidemiologic study estimated that the prevalence of SCC was 2 per 1,000 among persons in their forties, 8 per 1,000 in their fifties, and 15 per 1,000 in their sixties.28 The prevalence and incidence of squamous skin cancer in the United States are difficult to determine, since these cancers are not typically tracked by cancer registries and do not have a unique code in ICD-9. Based on indirect methods (extrapolation from population-based registries in British Columbia and in Portland, Oregon), the lifetime risk of developing squamous cell cancer has been estimated to be 9–14 percent in men and 4–9 percent in women in the U.S.29 The US age-adjusted incidence of SCC was estimated to be 106 per 100,000 men and 29.8 per 100,000 women in 1986 (also calculated indirectly using population-based registry data from Kaiser Permanente in Portland, Oregon).30 Rates vary geographically. A survey of one large health plan in Albuquerque, New Mexico found age-standardized incidence rates of 214 per 100,000 in nonhispanic white men and 50 per 100,000 in nonhispanic white women. A population-based study in Rochester, Minnesota covering the years 1976 to 1984 found age-standardized incidence rates of squamous cell cancer of 63.1 per 100,000 in men and 22.5 per 100,000 in women.31 In a population-based study of non-melanoma skin cancer in New Hampshire in 1993–1994, the age-adjusted incidence of squamous cell cancer was 97 per 100,000 men.32

## Diagnosis and Treatment of Actinic Keratoses

AKs are circumscribed, irregularly scaly, slightly raised lesions appearing on a background of solar-damaged skin.4, 33, 34 They are most often red, yellowish, or brown. Many are asymptomatic,7 but some cause pruritis, burning, or a splinter-like sensation in the skin. Because they occur most frequently in sun-exposed areas (face, head, neck, forearms, and hands), individuals (or their family members) notice them and may seek medical care because of concern that they may be cancerous or because they adversely affect appearance.

### Terminology

The term “actinic keratosis” was developed on the basis of clinical appearance and texture of these lesions without regard to histological appearance or pathogenesis. Histologically, AKs are a proliferation of atypical cells confined to the lower levels of the epidermis; criteria for the diagnosis of AK include parakeratosis, epidermal atrophy or thickening, and atypia. If microscopic examination reveals involvement of the dermis, the lesion is termed “invasive squamous cell carcinoma” (SCC); complete replacement of the epidermis by neoplastic cells without invasion of the dermis is called “squamous carcinoma-in-situ.” Histologically, then, the difference between AK and SCC is the extent and location of atypical keratinocytes, including the cytologic and nuclear appearance of the cells. Genetically, there is also a continuum, with concentrations of the p53 gene increasing from AK through invasive SCC.35

For about 100 years, AKs have been considered to be precancerous lesions, meaning that, while they are not cancers, they can progress to squamous cell cancer. Throughout this time some have objected to the term “precancerous” and the implication that AKs undergo some kind of malignant transformation or progression to become “cancer.”36 Critics of the concept of “precancerosis” argue that AK is a true cancer because the abnormal cells that define it are indistinguishable from those in squamous cell carcinoma.5, 37–40 They argue that, on the continuum from AK to carcinoma-in-situ to SCC, it is impossible to draw a meaningful distinction between what is and is not “cancer.” They also point to molecular similarities between SCC and AK, particularly the frequency of a specific p53 gene mutation on chromosome 17p and the high frequency of loss of heterozygosity.41 Therefore, they propose, the term “actinic keratosis” should be replaced by "keratinocytic intraepidermal neoplasia" or “incipient intraepidermal squamous cell carcinoma".38, 42

Proponents of the view that AKs are precancerous point out that AKs do not grow actively, frequently regress, and do not have the potential to metastasize. Consequently, such proponents support a definition of cancer based on the behavior of the neoplasm rather than on the appearance of the cells. They also point out that there are molecular similarities between AKs and sun-damaged skin without dysplasia,43 and that the mechanism of malignant transformation is an area of intense molecular research that has not as yet settled the issue of whether or not AKs should be classified as cancers.

### Diagnosis

Because of their characteristic appearance, AKs are usually diagnosed clinically, without confirmation by biopsy. In two small studies, the clinical diagnosis of AK was highly consistent with the histologic diagnosis. In one, a case series from one pathologist, dermatologists’ clinical diagnoses of AK were confirmed in 34 of 36 cases.44 In a subsample from a prospective, population-based study of AKs, 20 of 22 AKs were consistent with the histologic diagnosis made by a single pathologist. In a third study, conducted as part of a randomized trial of sunscreen in Maryborough, Australia, 48 randomly selected lesions diagnosed clinically to be AKs were biopsied.45 Of these, 39 (81 percent) were AKs histologically, using the criteria specified in the study (hyperkeratosis, epidermal thickening, and dysplasia). Six of the other nine lesions showed evidence of solar damage but lacked either hyperkeratosis or dysplasia, and the other three were lesions unrelated to AK.

The diagnosis of AK was less reliable in two studies of interobserver agreement, both by the same investigator and both using convenience samples from a dermatology clinic in a Veterans Affairs Medical Center. In one of these studies, two dermatologists examined 50 consecutive patients.46 Their agreement on the diagnosis of single AKs was poor (kappa statistic 0.17 and 0.15) They were much more likely to agree on the diagnosis of multiple AKs (kappa statistic 0.62 and 0.55). In the other study, primary care clinicians’ diagnoses were compared with that of a dermatologist.47 Agreement was moderate as to whether a patient had single actinic keratosis (kappa, 0.36; 95 percent confidence interval [CI], 0.22–0.50), multiple actinic keratoses (kappa, 0.48; 95 percent CI, 0.34–0.61), or skin cancer (kappa, 0.48; 95 percent CI, 0.34–0.62).

The clinical diagnosis of squamous cell carcinoma of the skin is less reliable. In an Australian study of 1,292 skin cancers from 1986, dermatologists were correct in their clinical diagnosis of SCC 51 percent of the time, versus 35 percent for surgeons and 15 percent for general practitioners.48 Other studies,44, 46, 47 as well as a large, recent series of 2,058 tumors removed by surgeons,49 confirm that the clinical diagnosis of skin cancer is imperfect.

### Treatment

Various modalities are used to treat actinic keratoses. The options include, but are not limited to, destruction, topical therapy, resurfacing, excision, or combinations. The treatment options are described in detail in Appendix 1.^50–53^

Clinicians may take numerous factors into consideration when choosing the most appropriate treatment for a patient. These include the anatomical location, size, and extent of the lesion(s), changes in lesion growth pattern, previous treatment, medical stability of the patient, and patient preference of therapeutic options.

## Key Questions

Key questions for this report were developed by the Agency for Healthcare Research and Quality (AHRQ) in consultation with the Health Care Finance Administration. After a draft of the questions was reviewed by representatives of dermatologic professional societies, AHRQ finalized the questions and assigned them to the Oregon Health Sciences University Evidence-based Practice Center. In consultation with AHRQ, OHSU refined the key questions, and used them to guide the literature search.

The key questions are listed in Table 1. These questions concern the logic underlying two strategies for management AKs: immediate treatment of all AKs versus monitoring plus selective removal of some AKs. The goal of immediate treatment is to prevent the development of invasive and metastatic cancer by destroying AKs before they can progress to SCC. This strategy assumes that, in the long run, periodic treatment of all AKs will reduce the number and duration of AKs. As a result, fewer squamous cell cancers will develop, and the reduced incidence of SCC will prevent the longer-term consequences of deeply invasive or metastatic cancer.

Table 1 Key questions

1. Do different management strategies or different methods of removal of the lesion lead to; a. different morbidity and mortality from SCC?; b. different incidence of SCC?; c. different number and duration of AKs?; d. different quality of life related to side effects and complications of treatment?
2. What is the natural history of actinic keratosis?; a. What is the incidence and regression rate of AKs?; b. In patients with actinic keratoses, what is the expected incidence of progression to invasive squamous cell carcinoma with and without removal of the lesion?
3. Will reducing the incidence of SCC reduce morbidity and mortality?; a. How often does SCC cause disfigurement or death, excluding immunocompromised patients and those with SCC originating on the lip,ear, or eye?; b. What proportion of disfiguring or lethal SCCs arise from AKs and are potentially preventable?
4. Risk assessment. Are there characteristics of actinic keratoses that can be used to identify lesions that are more likely to progress to invasive squamous cell carcinoma?
5a. Are there characteristics that can be used to identify a group of patients at higher risk of progression to invasive squamous cell carcinoma?
5b. Are there data to support a monitoring protocol that will allow detection and treatment of any squamous cell carcinoma at a sufficiently early stage?
5c. For patients who have multiple, recurrent actinic keratoses, do the effectiveness of the following management strategies differ:; -- immediate treatment of all AK’s; -- selective treatment of some AK’s, and watchful waiting for others, followed by selective treatment of those that persist, enlarge, or become suspected squamous cell cancers? By “effectiveness” we mean the impact on death, disfigurement and major surgical procedures due to SCC?

The alternative approach—monitoring patients with AK and selectively removing lesions that have developed characteristics suggesting progression to squamous cell cancer—rests on several assumptions about the natural history of AKs and SCC. One key assumption is that there are characteristics of AKs that predict progression to SCC. Another is that early detection of squamous cell cancers (rather than preventing them by removing AKs before they progress) will prevent the development of deeply invasive or metastatic cancer.