# Priorities for Future Research

Table 5 indicates that, for some key questions, no scientific evidence is available. Clinical research to address these information gaps is justified by several considerations. From 1 in 11 to 1 in 15 Medicare beneficiaries over 65 years of age have undergone treatment for AK at least once, and practice styles for the management of patients with AK are likely to vary considerably. Indirect evidence suggests that squamous cell cancer may cause significant morbidity and mortality in the elderly, especially elderly men.

The highest priorities for future research are

- controlled trials of different strategies for the long-term management of patients who have multiple, recurrent actinic keratoses,
- registry studies to assess morbidity and mortality related to squamous cell cancer in the elderly population, and to test hypotheses about geographic variation in incidence, prevalence, and practice patterns,
- patient-centered research on patients’ preferences for, and quality of life related to, different treatments.

## Research Priority 1: Controlled Trials of Management Strategies

A small proportion of patients with multiple, recurrent actinic keratoses account for a much larger proportion of utilization and morbidity from AKs, and are also at higher risk of developing SCC in the longer term. Most studies of different methods of removal of AKs focus on short-term results related to specific lesions, but do not take into account the long-term consequences of the high incidence of new lesions and the frequency of regression among prevalent lesions. Studies of AK treatments are too small and, in most cases, of too short duration to measure outcomes related to the main goals of treatment, including cancer prevention, improvement in appearance, and reducing or eliminating symptoms.

Future studies should examine comprehensive, longer-term strategies for managing these patients. A comprehensive approach explicitly considers short-term and long-term morbidity related to lesions and to the choice of treatment as well as long-term outcomes related to the goals of treatment: prevention of cancer, improved appearance, and reduction or prevention of discomfort. A comprehensive approach is needed because symptomatic and asymptomatic lesions occur in the same patient, and treatment decisions for asymptomatic lesions may be influenced by the need to treat symptomatic ones in the same region.

At present, very few data are available to assess the short- and long-term advantages and disadvantages of different management strategies, such as immediate treatment of all AKs versus selective treatment of some AKs, and monitoring for others. Because AKs have a high incidence and recurrence rate, both of these approaches require protocols for monitoring patients. In addition to their clinical impact, the choice of management strategies may have large resource implications, but these can be assessed only by studies that look beyond the initial approach to optimize the quality of care in the longer term.

## Research Priority 2: Registry Studies

The results of this review lend support to the view, expressed by a National Cancer Institute panel, to develop a registry of patients with squamous cell cancer. The main goals of registry research would be to assess morbidity and mortality related to squamous cell cancer in the elderly population, to better measure the relation between SCC and actinic keratosis, and to test hypotheses about geographic variation and cost-effectiveness related to practice patterns. Because morbidity and mortality from AK and SCC are concentrated in the elderly, a key step in a population-based database about these conditions is to introduce a unique diagnostic (ICD) code for squamous cell cancer, since the current 173.x code does not discriminate SCC from BCC or other NMSC.

## Research Priority 3: Measurement of Patient Preferences

Studies of treatments for AK provide little information about patients’ preferences for, and quality of life related to, different treatments. Because most treatments for AK are associated with some discomfort and alteration of appearance, compliance and quality of life are likely to be important factors in the long-term effectiveness and costs of alternative treatments. Observational studies, surveys, and controlled trials using general and disease-specific instruments to measure these factors should be conducted.