# Conclusions

Table 5 briefly summarizes the strengths and gaps in the evidence for each of the key questions.

Table 5 Summary of evidence for each key question

Key Question | Quality of Evidence | Comment
1. Do different management strategies or different methods of removal of the lesion lead to
a) different morbidity and mortality from SCC? | Poor | No data.
b) different incidence of SCC? | Good (sunscreen, beta carotene, retinol); Poor (other agents) | Among patients with AKs, use of sunscreen prevents SCC. Use of oral vitamin A may also prevent SCC, and beta-carotene does not. There are no data for other agents.
c) different number and duration of AKs? | Fair-Poor | 5-FU eliminates up to 75% of AKs in the short-term and some other treatments have equivalent short-term efficacy. One long-term followup study suggests that cryosurgery eliminates over 95% of AK's. Longer-term data is sparse and confounded by intervening treatments. Uncontrolled studies suggest that some treatments reduce the number of AK's up to 2 years.
d) different quality of life related to side effects and complications of treatment? | Poor | Little or no data about patient preferences and quality of life related to different treatment approaches.
2. In patients with actinic keratoses, what is the incidence, regression rate,and expected incidence of progression to invasive squamous cell carcinoma with and without removal of the lesion? | Good (without removal) Poor (with removal) | AKs are dynamic lesions; they frequently regress and recur spontaneously. Progression rates are 1–2 per 1,000 for average-risk persons in Australia. Rates are higher in individuals with risk factors (see below). It is not known whether clinically inapparent AKs can progress.
3. Will reducing the incidence of SCC reduce morbidity and mortality? | Fair-Poor | Indirect evidence suggest that 2% of SCCs arising from AKs metastasize, and 7–12% recur. However, accurate data on the morbidity associated with SCC are lacking, and there is no direct evidence of the magnitude of benefit from reducing the incidence of SCC.
4. Risk assessment. Are there characteristics of actinic keratoses that can be used to identify lesions that are more likely to progress to invasive squamous cell carcinoma? | Poor | There are no data linking characteristics of lesions to the risk of progression to SCC in the future.
5a. Are there characteristics that can be used to identify a group of patients at higher risk of progression to invasive squamous cell carcinoma? | Good | In good-quality prospective and cross-sectional studies, male sex, older age, prior history of skin cancer, continued sun exposure, and the number of AKs are associated with a higher risk of developing malignancy.
5b. Are there data to support a monitoring protocol that will allow detection and treatment of any squamous cell carcinoma at a sufficiently early stage? | Poor | There is no direct evidence, and too little is known about how often SCCs metastasize early to assess the effectiveness of monitoring to detect and treat SCC early in its course.
5c. For patients who have multiple, recurrent actinic keratoses, does the effectiveness of management strategies differ? | Poor | There are no studies comparing immediate treatment of all AKs to selective treatment and monitoring.

## Key Question 1 Do different management strategies or different methods of removal of the lesion lead to different outcomes?

There are no data comparing the effect of different management strategies or different methods of removal of AKs on incidence, morbidity, or mortality from squamous cell cancer. Among patients with AK, use of sunscreen prevents SCC. Treatment with 5-FU eliminates up to 75 percent of AKs in the short-term and some other treatments have equivalent short-term efficacy. Longer-term data are sparse and confounded by intervening treatments. Uncontrolled studies suggest that some treatments reduce the number of AKs up to 2 years. There are little or no data about patient preferences and quality of life related to different treatment approaches.

## Key Question 2 What is the natural history of AK?

AKs are dynamic lesions; they often regress and recur. There is good evidence that rates of progression to SCC are 1–2 per 1,000 AKs for average-risk persons in Australia. Rates are higher in individuals with risk factors, including multiple AKs. The progression rate of clinically inapparent AKs (that is, those in “remission”) has not been studied.

## Key Question 3 Will reducing the incidence of SCC reduce morbidity and mortality?

Indirect evidence suggests that 2 percent of SCCs arising from AK metastasize, and that 7–12 percent recur. However, accurate data on the morbidity associated with SCC are lacking, and there is no direct evidence of the magnitude of benefit from reducing the incidence of SCC.

## Key Question 4 Are there characteristics of actinic keratoses that can be used to identify lesions that are more likely to progress to invasive squamous cell carcinoma?

There are no data linking characteristics of lesions to the risk of progression to SCC in the future.

## Key Question 5a Are there characteristics that can be used to identify a group of patients at higher risk of progression to invasive squamous cell carcinoma?

In good-quality prospective and cross-sectional studies, male sex, older age, prior history of skin cancer, continued sun exposure, and the number of AKs are associated with a higher risk of developing malignancy.

## Key Question 5b Are there data to support a monitoring protocol that will allow detection and treatment of any squamous cell carcinoma at a sufficiently early stage?

There is no direct evidence, and too little is known about how often SCCs metastasize early to assess the effectiveness of monitoring to detect and treat SCC early in its course.

## Key Question 5c For patients who have multiple, recurrent actinic keratoses, does the effectiveness of different management strategies differ?

No studies compare immediate treatment of all AKs to selective treatment and monitoring.