# US Preventive Services Task Force Grading Criteria

The appendix is not available from the publisher at this time.