# Executive Summary

The lifetime risk of developing squamous cell cancer (SCC) of the skin has been estimated to be 9–14 percent in men and 4–9 percent in women in the US. Rates vary geographically, with the highest incidence in the South and Southwest. SCC accounts for fewer than 0.1 percent of all cancer deaths. However, SCC has the potential to metastasize and may account for up to 34 percent of deaths from skin cancer among persons 65 through 84 years of age, and 56 percent of deaths from skin cancer among persons 85 years and older.

Actinic keratoses (AKs) are precursors of squamous cell cancers. AKs occur most frequently in the elderly, especially elderly men, who are also at highest risk for death or disfigurement from squamous cell cancer. In the United States, destruction of AKs is the single most commonly performed dermatologic procedure in the outpatient setting.

Various modalities are used to treat actinic keratoses. The options include destruction, topical therapy, resurfacing, excision, or combinations. When choosing the most appropriate treatment for a patient, clinicians may consider numerous factors, including the anatomical location, size, and extent of the lesion(s), changes in lesion growth pattern, previous treatment, medical stability of the patient, and patient preference among therapeutic options. Although the incidence of actinic keratoses is related to proximity to the Equator, there is no scientific rationale for using different treatments in different regions.

In this paper, we examine evidence for the assumptions about the natural history and effectiveness of treatment that underlie different strategies for the management of AKs. Our assessment focuses on the choice of treatment for asymptomatic AKs except those on the lip, ear, or eyelid, in normal hosts. There is consensus that all AKs on the lip, ear, or eyelid, and those in immunocompromised patients should be removed. We specify “asymptomatic” patients because, in many cases, AKs are treated for reasons other than preventing progression to cancer. AKs may be painful or pruritic, or may have an adverse affect on appearance. As Marks, the most notable advocate of a conservative approach to managing AKs, wrote:

“…the question (is) whether or not treatment is justified in the prevention of morbidity and mortality due to squamous cell carcinoma. This discussion needs to be kept on that focus. It is not about whether or not AKs should be treated on the basis of symptoms, cosmetic appearance, or recent change, or merely because the patient does not want to have an abnormality. The treatment of AKs under these circumstances is justified and is part of overall patient care, not for preventing problems due to SCC.”

## Key Questions

Key questions for this report were developed by the Agency for Healthcare Research and Quality (AHRQ) in consultation with the Health Care Finance Administration. After a draft of the questions was reviewed by representatives of dermatologic professional societies, AHRQ finalized the questions and assigned them to the Oregon Health Sciences University Evidence-based Practice Center. In consultation with AHRQ, OHSU refined the key questions, and used them to guide the literature search. The questions concern the logic underlying two strategies for management AKs: treatment of all AKs versus monitoring plus selective removal of some AKs. The logic underlying treatment of all AKs depends on a series of assumptions about the course and treatment of AKs. Specifically, this strategy assumes that periodic treatment will reduce the number and duration of AKs in the long run; as a result, fewer invasive squamous cell cancers will develop; and reducing the incidence of SCC will prevent the longer-term consequences of deeply invasive or metastatic cancer. The alternative approach—monitoring patients with AK and selectively removing lesions that have developed characteristics suggesting progression to invasive squamous cell cancer—also rests on several assumptions about the natural history of AKs and SCC. One key assumption is that there are characteristics of AKs that predict progression to invasive SCC. Another is that early detection of invasive squamous cell cancers (rather than preventing them by removing AKs before they progress) will prevent the development of deeply invasive or metastatic cancer.

## Methods

We searched MEDLINE from January 1966 to January 2001, the Cochrane Controlled Trials Registry, our own bibliographic databases of articles about skin cancer, and reference lists of published reviews and other studies to identify studies related to these questions. We abstracted information about the patient populations, interventions (when applicable), outcome measures, and characteristics of the study design from 45 articles that contained data relevant to one or more key questions. We used criteria developed by the US Preventive Services Task Force to classify articles as good, fair, or poor for their study design category (for example, controlled trial or cohort study).

## Results

### Do different treatments or different methods of removal of the lesion lead to different outcomes?

In the short-term (3–4 months), initial courses of 5-fluorouracil (5-FU), photodynamic therapy, or a medium depth chemical peel with trichloroacetic acid (TCA) reduced the number of visible AKs by 75% to 80%. .For other topical treatments, short-term results are poorer (e.g. tretinoin diclofenac) or less well-studied, and long-term results are not available. For cryosurgery, in one fair-quality cohort study of 70 patients followed for 1 year to 8.5 years, only 12 of 1,018 AKs recurred. There is fair to good evidence 5-FU, chemical peels, dermabrasion, and extensive cryosurgery peeling with liquid nitrogen reduce the total number of visible AKs one or more years after treatment. For example, mean number of visible AKs per patient from 15 or 16 before treatment to 2 to 4 after treatment. The longest followup evaluation of 5-FU treatment was published in 1972; it reported that 25 percent of patients required retreatment for recurrent or new AKs within 2 years of treatment, and 50 percent within 3 years.

No studies reported on how different methods of treating AKs affect morbidity and mortality from SCC or the incidence of SCC. There are also no studies of the effect of different treatments on patients’ quality of life in the long run.

### In patients with actinic keratoses, what is the a) incidence and regression rate b) incidence of progression to invasive squamous cell carcinoma with and without removal of the lesion?

Over the course of a year, from 20 to 25 percent of AKs regress. In one good-quality study, AKs that were present on the first examination had a higher regression rate (74 percent) than those that were not present on the first examination but developed before a later visit (29 percent). It is unclear how often spontaneous regression is permanent. Over the course of a year, 15 percent of the prevalent AKs that regressed later reappeared.

Two good-quality, prospective, longitudinal studies suggest that the yearly rate of progression of an AK to an invasive SCC in an average-risk person in Australia is between 8 and 24 per 10,000. A high rate of progression (12 percent) over 5 years was observed in the SKICAP-AK study, a large, controlled trial of retinol supplementation conducted in Arizona.

### Will reducing the incidence of SCC reduce morbidity and mortality?

Indirect evidence suggests that 2 percent of invasive SCCs arising from AK metastasize leading to significant morbidity and/or death, and that 7–12 percent recur. Accurate data on the morbidity associated with invasive SCC are lacking, and there is no direct evidence of the magnitude of benefit from reducing the incidence of invasive SCC.

A monitoring strategy assumes that metastasis or deep local invasion from a SCCoccurs long after an AK progesses to an invasive SCC. If metastasis or deep local invasion can occur soon after an AK progresses to invasive SCC, treatment of all AKs will reduce morbidity and mortality caused by invasive SCC more effectively than the monitoring strategy. Only one case series attempted to examine whether delay in treatment was related to the likelihood of metastasis. In that series three (2.5 percent) of 119 metastatic tumors had a diagnostic delay time of less than a month, and another 42 (35.3 percent) had a delay of 1 to 6 months.

### Are there characteristics of actinic keratoses that can be used to identify lesions that are more likely to progress to invasive squamous cell carcinoma?

We found no studies that measured the ability of characteristics of AK to predict progression to invasive SCC.

### Are there data to support a monitoring protocol that will allow detection and treatment of any squamous cell carcinoma at a sufficiently early stage?

In developing a monitoring protocol, one consideration is whether a high-risk group of patients can be identified prospectively. Good-quality epidemiologic studies clearly show that the number of AKs or the presence of AKs is a strong predictor of SCC. Among immonucompetent patients who have AKs, a prior history of skin cancer is the strongest predictor of the development of invasive SCC. Gender, burning exposure, skin type, and age are also risk factors. A high-risk patient may have a 30 percent risk of developing SCC over 5 years. A small percentage of individuals with AKs had a major proportion of the burden of illness. In one prospective study, 9 of the 47 men (about 20 percent) had 73 percent of the AKs. Four of the 46 women (9 percent) had 67 percent of the AKs. This concentration of the burden of illness suggests that the risk of developing SCC is concentrated in patients with multiple AKs. This concentration does not affect the benefit of initial treatment for a particular AK, whether in a patient who has several or only one. It does mean that, over time, the overall effectiveness of a monitoring program will depend in large part on how frequently patients who have large numbers of AKs are seen and how aggressively they are managed.

There are no studies of the results of monitoring patients with AK to detect and treat invasive SCC when it arises. Available data are insufficient to determine whether immediate treatment of all AKs, or a strategy of selective treatment for AKs that develop suspicious characteristics, result in different outcomes.

### For patients who have multiple, recurrent actinic keratoses, does the effectiveness of different management strategies differ?

No studies compared treatment of all AKs to selective treatment and monitoring.

## Conclusions

Treatment with 5-FU eliminates up to 75 percent of AKs in the short-term.with cryosurgery having at least comporable short-term efficacy. Longer-term data are sparse and confounded by intervening treatments. Uncontrolled studies suggest that some treatments reduce the number of AKs up to 2 years. There are little or no data about patient preferences and quality of life related to different treatment approaches. This is a striking omission as patient preferences are often decisive in choosing among treatment modalities in clinical practice.

There is good evidence that progression rates are 1–2 per 1,000 AKs per year for average-risk persons in Australia. Indirect evidence suggests that 2 percent of invasive SCCs arising from AK metastasize, and that 7–12 percent recur. In good-quality prospective and cross-sectional studies, male sex, older age, prior history of skin cancer, continued sun exposure, and the number of AKs are associated with a higher risk of developing malignancy. Patients with several of these risk factors (for example, multiple AKs and a prior history of skin cancer) have a 21–36 percent risk of developing invasive SCC over 5 years. However, there are no data linking characteristics of lesions themselves to the risk of progression to SCC in the future.

There are no data comparing the effect of different management strategies or different methods of removal of AKs on incidence, morbidity, or mortality from invasive SCC. We found no studies comparing immediate treatment of all AKs to selective treatment and monitoring. Little is known about the chance that an invasive SCC will metastasize early, before a monitoring protocol detects it.

## Priorities for Future Research

The highest priorities for future research are:

- controlled trials of different strategies and comparative treatment modalities for the long-term management of patients who have actinic keratoses, especially those with multiple actinic keratoses.
- registry studies to assess morbidity and mortality associated with squamous cell cancer in the elderly population, assess the value of characteristics of AKs for predicting progression to invasive SCC, and to test hypotheses about geographic variation in incidence, prevalence, and practice patterns,
- patient-centered research on preferences for, and quality of life related to, different treatments.