# References

1 Marks R, Rennie G, Selwood TS. Malignant transformation of solar keratoses to squamous cell carcinoma. Lancet. 1988;1(8589):795-797. [pmid: 2895318].
2 Mittelbronn MA, Mullins DL, Ramos-Caro FA, Flowers FP. Frequency of pre-existing actinic keratosis in cutaneous squamous cell carcinoma. Int J Dermatol. 1998;37(9):677-681. [pmid: 9762818].
3 Dinehart SM, Nelson-Adesokan P, Cockerell C, Russell S, Brown R. Metastatic cutaneous squamous cell carcinoma derived from actinic keratosis. Cancer. 1997;79(5):920-923. [pmid: 9041154].
4 Callen JP, Bickers DR, Moy RL. Actinic keratoses. J Am Acad Dermatol. 1997;36(4):650-653. [pmid: 9092763].
5 Cohn BA. From sunlight to actinic keratosis to squamous cell carcinoma. J Am Acad Dermatol. 2000;42(1 Pt 1):143-144. [pmid: 10607337].
6 Dodson JM, DeSpain J, Hewett JE, Clark DP. Malignant potential of actinic keratoses and the controversy over treatment. A patient-oriented perspective. Arch Dermatol. 1991;127(7):1029-1031. [pmid: 2064402].
7 Schwartz RA. The actinic keratosis. A perspective and update. [Review]. Dermatol Surg. 1997;23(11):1009-1019. quiz 20-1. [pmid: 9391557].
8 Marks R. The role of treatment of actinic keratoses in the prevention of morbidity and mortality due to squamous cell carcinoma. Arch Dermatol. 1991;127(7):1031-1033. [pmid: 2064403].
9 Petrovich Z, Parker R, Luxton G. Carcinoma of the lip and selected sites of the head and neck and skin: a clinical study of 896 patients. Radiother Oncol. 1987;8:11-17. [pmid: 3809597].
10 DeVries N. Metastasis of squamous cell carcinoma of the skin and lip. Dermatologica. 1969;138:333-339. [pmid: 5771648].
11 Rowe D, Carroll R, Day C. Prognostic factors for local recurrence, metastasis and survival rates in squamis cell carcinoma of the skin, ear and lip. J Am Acad Dermatol. 1992;26:976-990. [pmid: 1607418].
12 Otley CC, Pittelkow MR. Skin cancer in liver transplant recipients. [Review]. Liver Transpl Surg. 2000;6(3):253-262.
13 Fleischer AB Jr, Feldman SR, White RE, Leshin B, Byington R. Procedures for skin diseases performed by physicians in 1993 and 1994: analysis of data from the National Ambulatory Medical Care Survey. J Am Acad Dermatol. 1997;37:719-724. [pmid: 9366816].
14 Smith ES, Feldman SR, Fleischer AB Jr, Leshin B, McMichael A. Characteristics of office-based visits for skin cancer. Dermatologists have more experience than other physicians in managing malignant and premalignant skin conditions. Dermatol Surg. 1998;24(9):981-985. [pmid: 9754086].
15 Nestor M. The incidence of nonmelanoma skin cancers and actinic keratoses in South Florida. Paper presented at: Annual Meeting of the Florida Society of Dermatology. June 6, 1997. 1997.
16 Marks R, Jolley D, Dorevitch A, Selwood T. The incidence of non-melatonic skin cancer in an Australian population: results of a five year prospective study. Med J Aust. 1989;150:475-478. [pmid: 2786135].
17 Marks R, Selwood T. Solar keratoses: the association with erythemal ultraviolet radiation in Australia. Cancer. 1985;56:2332-2336. [pmid: 4052976].
18 Zagula-Mally Z, Rosenberg E, Kashagarian M. Frequency of skin cancer and solar keratoses in a rural southern county as determined by population sampling. Cancer. 1974;34:349.
19 Cooper SP, Downs T, Burau K, Buffler PA, Tucker S, Whitehead L, et al. A survey of actinic keratoses among paraquat production workers and a nonexposed friend reference group. Am J Ind Med. 1994;25(3):335-347. [pmid: 8160654].
20 Memon AA, Tomenson JA, Bothwell J, Friedmann PS. Prevalence of solar damage and actinic keratosis in a Merseyside population. Br J Dermatol. 2000;142(6):1154-1159. [pmid: 10848739].
21 Harvey I, Frankel S, Marks R. Non-melanoma skin cancer and solar keratoses: I. Methods and descriptive results of the South Wales Skin Cancer Study. Br J Cancer. 1996;74:1302-1307. [pmid: 8883422].
22 Epstein E, Epstein N, Bragg K. Metastases from squamous cell carcinomas of the skin. Arch Dermatol. 1968;97:245-251. [pmid: 5641327].
23 Weinstock M. Deaths from skin cancer among the elderly: epidemeiological patterns. Arch Dermatol. 1997;133:1207-1209. [pmid: 9382558].
24 Karjalainen S, Salo H, Teppo L. Basal cell and squamous cell carcinoma of the skin in Finland: Site distribution and patient survival. Int J Dermatol. 1989;28:445-450. [pmid: 2777443].
25 Preston DS, Stern RS. Nonmelanoma cancers of the skin. N Engl J Med. 1992;327(23):1649-1662. [pmid: 1435901].
26 Stern RS, Lunder EJ. Risk of squamous cell carcinoma and methoxsalen (psoralen) and UV-A radiation (PUVA). A meta-analysis. Arch Dermatol. 1998;134(12):1582-1585. [pmid: 9875197].
27 Osterlind A, Hjalgrim H, Kulinsky B, Frentz G. Skin cancer as a cause of death in Denmark. Br J Dermatol. 1991;125(6):580-582. [pmid: 1760365].
28 Green A, Beardmore G, Hart V. Skin cancer in a Queensland population. J Am Acad Dermatol. 1988;19:129-138. [pmid: 3403732].
29 Miller D, Weinstock M. Nonmelanoma skin cancer in the United States: incidence. J Am Acad Dermatol. 1994;50:774-778. [pmid: 8176018].
30 Glass A, Hoover R. The emerging epidemic of melanoma and squamous cell skin cancer. JAMA. 1989;262:2097-2100. [pmid: 2795783].
31 Chuang TY, Popescu NA, Su WP, Chute CG. Squamous cell carcinoma. A population-based incidence study in Rochester, Minn. rch Dermatol. 1990;126(2):185-188.
32 Karagas MR, Greenberg ER, Spencer SK, Stukel TA, Mott LA. Increase in incidence rates of basal cell and squamous cell skin cancer in New Hampshire, USA. New Hampshire Skin Cancer Study Group. Int J Cancer. 1999;81(4):555-559. [pmid: 10225444].
33 Barnaby JW, Styles AR, Cockerell CJ. Actinic keratoses. Differential diagnosis and treatment. Drugs Aging. 1997;11(3):186-205. [pmid: 9303279].
34 Frost CA, Green AC. Epidemiology of solar keratoses. Br J Dermatol. 1994;131(4):455-464. [pmid: 7947197].
35 Leffell DJ. The scientific basis of skin cancer. J Am Acad Dermatol. 2000;42:S18-S22.
36 Heaphy MR Jr, Ackerman AB. The nature of solar keratosis: a critical review in historical perspective. J Am Acad Dermatol. 2000;43(1 Pt 1):138-150. [pmid: 10863242].
37 Evans C, Cockerell CJ. Actinic keratosis: time to call a spade a spade. South Med J. 2000;93(7):734-736. [pmid: 10923970].
38 Cockerell CJ. Histopathology of incipient intraepidermal squamous cell carcinoma ("actinic keratosis"). [Review]. J Am Acad Dermatol. 2000;42(1 Pt 2):11-17. [pmid: 10607351].
39 Cohn BA. Squamous cell carcinoma: could it be the most common skin cancer? [letter; comment]. J Am Acad Dermatol. 1998;39(1):134-136. [pmid: 9674413].
40 Lober BA, Lober CW. Actinic keratosis is squamous cell carcinoma. [Review]. South Med J. 2000;93(7):650-655. [pmid: 10923948].
41 Rehman I, Quinn A, Healy E, Rees J. High frequency of loss of heterozygosity in actinic keratoses, a usually benign disease. Lancet. 1994;344:788-789. [pmid: 7916075].
42 Yantsos VA, Conrad N, Zabawski E, Cockerell CJ. Incipient intraepidermal cutaneous squamous cell carcinoma: a proposal for reclassifying and grading solar (actinic) keratoses. Semin Cutan Med Surg. 1999;18(1):3-14. [pmid: 10188837].
43 Einspahr J, Alberts DS, Aickin M, Welch K, Bozzo P, Grogan T, et al. Expression of p53 protein in actinic keratosis, adjacent, normal-appearing, and non-sun-exposed human skin. Cancer Epidemiol Biomarkers Prev. 1997;6(8):583-587. [pmid: 9264270].
44 Ponsford M, Goodman G, Marks R. The prevalence and accuracy of diagnosis of non-melanotic skin cancer in Victoria. Australas J Dermatol. 1983;24:79-82. [pmid: 6661117].
45 Thompson SC, Jolley D, Marks R. Reduction of solar keratoses by regular sunscreen use. N Engl J Med. 1993;329(16):1147-1151. [pmid: 8377777].
46 Whited JD, Horner RD, Hall RP, Simel DL. The influence of history on interobserver agreement for diagnosing actinic keratoses and malignant skin lesions. J Am Acad Dermatol. 1995;33(4):603-607. [pmid: 7673492].
47 Whited JD, Hall RP, Simel DL, Horner RD. Primary care clinicians' performance for detecting actinic keratoses and skin cancer [published erratum appears in Arch Intern Med 1997 Aug 11–25;157(15):1686]. Arch Intern Med. 1997;157(9):985-990. [pmid: 9140269].
48 Nixon R, Dorevitch A, Marks R. Squamous cell carcinoma of the skin: accuracy of clinical diagnosis and outcome of followup in Australia. Med J Aust. 1986;144:235-237. [pmid: 3587093].
49 Hallock GG, Lutz DA. Prospective study of the accuracy of the surgeon's diagnosis in 2000 excised skin tumors. Plast Reconstr Surg. 1998;101(5):1255-1261. [pmid: 9529210].
50 Feldman SR, Fleischer AB Jr, Williford PM, Jorizzo JL. Destructive procedures are the standard of care for the treatment of actinic keratoses. J Am Acad Dermatol. 1999;40:43-47. [pmid: 9922011].
51 Kurwa HA, Barlow RJ. The role of photodynamic therapy in dermatology. Clin Exp Dermatol. 1999;24(3):143-148. [pmid: 10354165].
52 Dillaha CJ, Jansen GT, Honeycutt WM, Bradford AC. Selective cytotoxic effect of topical 5-fluorouracil. Arch Dermatol. 1983;119:774-783. [pmid: 6614965].
53 Pearlman D. Weekly pulse dosing: effective and comfortable topical 5-fluorouracil treatment of multiple facial actinic keratoses. J Am Acad Dermatol. 1991;25:665-667. [pmid: 1791225].
54 Helfand M, Mahon S, Eden K. Screening for skin cancer. Am J Prev Med. 2001;20(3S):47-58. [pmid: 11306232].
55 Griffin TD, Van Scott EJ. Use of pyruvic acid in the treatment of actinic keratoses: a clinical and histopathologic study. Cutis. 1991;47(5):325-329. [pmid: 2070654].
56 Jiang SB, Levine VJ, Nehal KS, Baldassano M, Kamino H, Ashinoff RA. Er:YAG laser for the treatment of actinic keratoses. Dermatol Surg. 2000;26(5):437-440. [pmid: 10816231].
57 Grimaitre M, Etienne A, Fathi M, Piletta PA, Saurat JH. Topical colchicine therapy for actinic keratoses. Dermatology. 2000;200:346-348. [pmid: 10894974].
58 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Methods of the third U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
59 Marks R, Foley P, Goodman G, Hage BH, Selwood TS. Spontaneous remission of solar keratoses: the case for conservative management. Br J Dermatol. 1986;115(6):649-655. [pmid: 3801305].
60 Moon TE, Levine N, Cartreel B, Bangert JL, Rodney S, Dong Q, et al. Effect of retinol in preventing squamous cell skin cancer in moderate- risk subjects: A randomized, double-blind, controlled trial. Cancer Epidemiol Biomarkers Prev. 1997;6(11):949-956. [pmid: 9367069].
61 Naylor MF, Boyd A, Smith DW, Cameron GS, Hubbard D, Neldner KH. High sun protection factor sunscreens in the suppression of actinic neoplasia. Arch Dermatol. 1995;131(2):170-175. [pmid: 7857113].
62 Green A, Battistutta D, Hart V, Leslie D, Marks G, Williams G, et al. The Nambour Skin Cancer and Actinic Eye Disease Prevention Trial: design and baseline characteristics of participants. Control Clin Trials. 1994;15:512-522. [pmid: 7851112].
63 Black H. Influence of dietary factors on actinically-induced skin cancer. Mutat Res. 1998;422:185-190. [pmid: 9920444].
64 Moon TE, Levine N, Cartmel B, Bangert JL. Retinoids in prevention of skin cancer. Cancer Lett. 1997;114(1–2):203-205. [pmid: 9103292].
65 Moon TE, N L, B C, J B, S R, M S, et al. Design and recruitment for retinoid skin cancer prevention (SKICAP) trials. Cancer Epidemiol Biomarkers Prev. 1995;4:661-669. [pmid: 8547834].
66 Lubritz RR, Smolewski SA. Cryosurgery cure rate of actinic keratoses. J Am Acad Dermatol. 1982;7(5):631-632. [pmid: 7142470].
67 Jeffes EW, McCullough JL, Weinstein GD, Fergin PE, Nelson JS, Shull TF, Simpson KR, Bukaty LM, Hoffman WL, Fong NL. Photodynamic therapy of actinic keratosis with topical 5-aminolevulinic acid. A pilot dose-ranging study. Arch Dermatol. 1997;133:727-732. [pmid: 9197826].
68 Omrod D, Jarvis B. Topical Aminolevulinic Acid HCl Photodynamic Therapy. Am J Clin Dermatol. 2000;1(2):133-139. [pmid: 11702313].
69 Kurwa HA, Yong-Gee SA, Seed PT, Markey AC, Barlow RJ. A randomized paired comparison of photodynamic therapy and topical 5-fluorouracil in the treatment of actinic keratoses. J Am Acad Dermatol. 1999;41:414-418. [pmid: 10459115].
70 Bercovitch L. Topical chemotherapy of actinic keratoses of the upper extremity with tretinoin and 5-fluorouracil: a double-blind controlled study. Br J Dermatol. 1987;116(4):549-552. [pmid: 3555597].
71 Lawrence N, Cox SE, Cockerell CJ, Freeman RG, Cruz PD Jr. A comparison of the efficacy and safety of Jessner's solution and 35% trichloroacetic acid vs 5% fluorouracil in the treatment of widespread facial actinic keratoses. Arch Dermatol. 1995;131(2):176-181. [pmid: 7857114].
72 Simmonds WL. Double-Blind Investigation Comparing a 1%-vs-5% 5-Fluorouracil Topical Cream in Patients with Multiple Actinic Keratoses. Cutis. 1973;12:615-617.
73 Witheiler DD, Lawrence N, Cox SE, Cruz C, Cockerell CJ, Freemen RG, Brody HJ. Long-term efficacy and safety of Jessner's solution and 35% trichloroacetic acid vs 5% fluorouracil in the treatment of widespread facial actinic keratoses. Dermatol Surg. 1997;23:191-196. [pmid: 9145962].
74 Simmonds WL. Topical management of actinic keratoses with 5-fluorouracil: results of a 6-year follow-up study. Cutis. 1972;10:737-741.
75 Anonymous. Carac Cream 0.5%: FDA. 2000.
76 Alirezai M, Dupuy P, Amblard P, Kalis B, Souteyrand P, Frappaz A, et al. Clinical evaluation of topical isotretinoin in the treatment of actinic keratoses. J Am Acad Dermatol. 1994;30:447-451. [pmid: 8113458].
77 Misiewicz J, Sendagorta E, Golebiowska A, Lorenc B, Czarnetzki BM, Jablonska S. Topical treatment of multiple actinic keratoses of the face with arotinoid methyl sulfone (Ro 14-9706) cream versus tretinoin cream: a double-blind, comparative study. J Am Acad Dermatol. 1991;24:448-451. [pmid: 2061443].
78 Anonymous. Solaraze: FDA. 2000.
79 Marrero GM, Katz BE. The new fluor-hydroxy pulse peel. A combination of 5-fluorouracil and glycolic acid. Dermatol Surg. 1998;24:973-978. [pmid: 9754085].
80 Tse Y, Ostad A, Lee HS, Levine VJ, Koenig K, Kamino H, et al. A clinical and histologic evaluation of two medium-depth peels. Glycolic acid versus Jessner's trichloroacetic acid. Dermatol Surg. 1996;22(9):781-786. [pmid: 8874526].
81 Chiarello SE. Cryopeeling (extensive cryosurgery) for treatment of actinic keratoses: an update and comparison. Dermatol Surg. 2000;26(8):728-732. [pmid: 10940057].
82 Coleman WP 3rd, Yarborough JM, Mandy SH. Dermabrasion for prophylaxis and treatment of actinic keratoses. Dermatol Surg. 1996;22(1):17-21. [pmid: 8556252].
83 Frost C, Williams G, Green A. High incidence and regression rates of solar keratoses in a queensland community. J Invest Dermatol. 2000;115(2):273-277. [pmid: 10951246].
84 Solomons B. Lecture notes in dermatology. 5th ed. Oxford. Blackwell. 1983.
85 Sauer GC. Manual of skin diseases. Fifth ed. Philadelphia. Lippincott. 1985.
86 Montgomery MH, Dorffel J. Verruca senilis und Keratoma senile. Arch Dermat Syphil (Berlin). 1932;166:286-297.
87 Glogau RG. The risk of progression to invasive disease. J Am Acad Dermatol. 2000;42(1 Pt 2):23-24. [pmid: 10607353].
88 Graham JH, Graham GF. Solar keratosis and skin cancer. Paper presented at: Annual Meeting, North American Clinical Dermatologic Society. St. Petersburg, Russia. 2000.
89 Graham J. Precancerous lesions of the skin. Prim Care. 1976;2:699-716.
90 Bendl BJ, Graham JH. New concepts on the origin of squamous cell carcinomas of the skin: solar (senile) keratosis with squamous cell carcinoma--a clinicopathologic and histochemical study. Proc Natl Cancer Conf. 1971;6:471-488. [pmid: 5458117].
91 Dinehart SM, Pollack S. Metastases from squamous cell carcinoma of the skin. J Am Acad Dermatol. 1989;21:241-248. [pmid: 2768574].
92 Lund H. How often does squamous cell carcinoma of the skin metastasize?. Arch Dermatol. 1965;92:635-637. [pmid: 5846318].
93 Fukamizu H, Inoue K, Matsumoto K. Metastatic squamous cell carcinomas derived from solar keratosis. J Dermatol Surg Oncol. 1985;11:518-522. [pmid: 3998264].
94 Silverstone H, Searle J. The epidemiology of skin cancer in Queensland: the influence of phenotype and environment. Br J Cancer. 1970;24:235-252. [pmid: 5451567].
95 Marks R, Ponsford M, Selwood T. Non melanomatic skin cancer and solar keratoses in Victoria. Med J Aust. 1983;2:619-622. [pmid: 6669125].
96 Marks R, Staples M, Giles G. Trends in non-melanoma skin cancer treated in Australia: the second national survey. Int J Cancer. 1993;53:585-590. [pmid: 8436431].
97 Giles G, Marks R, Foley P. Incidence of non-melanocytic skin cancer treated in Australia. BMJ. 1988;296:13-17. [pmid: 3122913].
98 Green A, Battistutta D. Incidence and determinants of skin cancer in a high risk Australian population. Int J Cancer. 1990;15:356-361. [pmid: 2394501].
99 Marks R, Jolley D, Lecastas S. The role of childhood sunlight exposure in the development of solar keratoses and non melanoma skin cancer. Med J Aust. 1990;152:62-65. [pmid: 2296232].
100 English D, Armstrong B, Kricker A. Demographic characteristics, pigmentary and cutaneous risk factors for squamous cell carncinoma of the skin: a case control study. Int J Cancer. 1998;76:628-634. [pmid: 9610717].
101 Vitasa B, Taylor H, Strickland P. Association on non-melanoma skin cancer and actinic keratosis with cumulative solar ultraviolet exposure in Maryland watermen. Cancer. 1990;65:2811-2817. [pmid: 2340474].
102 Marks R, Rennie G, Selwood T. The relationship of basal cell carcinomas and squamous cell carcinomas to solar keratoses. Arch Dermatol. 1988;124(7):1039-1042. [pmid: 3389848].