# Methods

We conducted a comprehensive search of the scientific literature to identify relevant studies addressing the key questions. The intent of this review was not to assess the quality of individual studies or to analyze their results. We identified the uses of HBOT in the adult population using the following algorithm (Figure 1):

1. We first searched the websites of CMS, Undersea and Hyperbaric Medical Society (UHMS), and healthcare insurers such as Aetna, Blue Cross and Blue Shield, and CIGNA to come up with an initial list of the covered and non-covered uses of HBOT.
2. We supplemented this list by searching published TAs, systematic reviews and clinical trials that assessed the uses of HBOT.
3. Finally we searched case reports and textbooks for any new uses that were not addressed in RCTs and observational studies

The result of the above search is shown in Table 1. For Question 2, we tallied the number and type of studies for each of the HBOT uses we identified in Question 1, also shown in Table 1. In addition to the summary table, we provided a brief narrative text describing the evidence as reported in these studies for each of the outcomes. For Question 3, we searched for the overall conclusions and estimate of effect, if available, as reported in the systematic reviews and/or RCTs. Because HBOT for CO poisoning and wounds are already covered by CMS, in discussions with CMS and AHRQ, it was decided to include a brief narrative review of the literature on these topics.

## Literature Search Strategy

We searched MEDLINE (1966 to December, 2005) for studies of adults in English language to identify articles relevant to each key question. We conducted a supplemental search of the Cochrane Database of Systematic Reviews, National Guidelines Clearinghouse, other appropriate databases for any evidence-based guidelines, and AHRQ databases of technology assessments. We also searched reference lists of selected review articles and textbook chapters on HBOT. In searches of electronic databases, we combined terms for hyperbaric oxygen and relevant research designs (see Appendix A for complete search strategy).

### Selection criteria

We included studies of any size and study designs including systematic reviews with or without meta-analysis, RCT, non-randomized comparative studies, cohort studies, case-control studies, and retrospective case series. We included studies reporting any clinical endpoint and intermediate outcomes. Case reports for novel uses of HBOT i.e., not covered by RCTs or cohort studies were also included. For the section on the wounds, we updated studies published after August 2001, the date of the last literature search of the previous Tufts-NEMC EPC TA on HBOT in treatment of hypoxic wounds. We excluded studies that evaluated HBOT in healthy human volunteers and protocols of systematic reviews, and RCTs that evaluated no human subjects. We excluded from analysis studies of well-established indications of HBOT, these included decompression illnesses and air and gas embolism. The adverse events of HBOT were beyond the scope of this report. Studies exclusively of topical HBOT were also excluded. We did not include foreign language publications whose abstracts were indexed in English language. Also excluded were narrative reviews, published commentaries, and letters.

### Data abstraction and synthesis

Results from previously conducted TAs and systematic reviews on these topics were sought and used where appropriate. In addition, qualitative reviews on the specific topics from individual studies were conducted. Evidence tables of study characteristics and relevant results were compiled to summarize the uses of HBOT. Because the aim of this report was to identify reported uses of HBOT, individual studies were not critically appraised to determine the validity of their results or conclusions. Items extracted included first author, publication year, country where the study was conducted, study design, number of patients enrolled in the study, topic of the study, and application of the HBOT. For systematic reviews we recorded the overall conclusions and estimate of effect when available. The estimate of effect from any new studies of RCTs identified in our search was also described. Results of data extraction were presented in structured evidence tables (Appendix D) and also as a narrative description.

Figure 1 Horizon Scan of hyperbaric oxygen therapy (HBOT). Steps to identify uses of HBOT. Arrows depict studies sought to address key questions

Horizon Scan of hyperbaric oxygen therapy (HBOT). Steps to identify uses of HBOT. Arrows depict studies sought to address key questions.