# Discussion / Limitations

This report summarizes the published uses of HBOT in the adult population identified through a systematic literature search. The main purpose of this review was to identify studies that reported or assessed the uses of HBOT but not to perform critical evaluations of the studies for each of the uses we identified. Because HBOT for CO poisoning and wounds are already covered by CMS, in discussions with CMS and AHRQ, it was decided to include a brief narrative review of the literature on these topics. Our report relied primarily on the published TAs and systematic reviews but did not evaluate both included and rejected primary studies reviewed by them. We included only those individual studies published subsequent to the most recent TAs and systematic reviews. We did not critically appraise TAs, systematic reviews and individual studies, as the intent of this review was not to assess the quality of studies or analyze their results. We reported authors’ conclusions without critical assessment. We also did not include any published commentaries that critically addressed the deficiencies and flaws of the included TAs, systematic reviews, and individual studies on the uses of HBOT.