# References of included case reports

The appendix is not available from the publisher at this time.