# MEDLINE search strategy

The appendix is not available from the publisher at this time.