# References

1 Jain KK. Textbook of hyperbaric medicine. Toronto. Hogrefe & Huber Publishers. 2004. 4th. ed.
2 Medical Services Advisory Committee (MSAC) application 1018-1020. Assessment report ISSN 1443-7120. 2000. http://www.msac.gov.au.
3 Agence d'evaluation des technologies et des modes d'intervention en sante. Hyperbaric oxygen therapy in Quebec (AETMIS 2000-3 RE). Montreal. AETMIS. 2001.
4 Dent T. Hyperbaric oxygen therapy for carbon monoxide poisoning. Succinct and Timely Evaluated Evidence Review (STEER). 2002. http://www.signpoststeer.org. Report No.: 13.
5 Mitton C, Hailey D. Hyperbaric oxygen in Alberta. Alberta Heritage Foundation for Medical Research (AHFMR). 1998. http://www.ahfmr.ab.ca/hta/hta-publications/reports/hbot.php.
6 Juurlink DN, Stanbrook MB, McGuigan MA. Hyperbaric oxygen for carbon monoxide poisoning. Cochrane Database of Systematic Reviews. 2000;(2):CD002041. [pmid: 10796853].
7 Raphael JC, Elkharrat D, JarsGuincestre MC, Chastang C, Chasles V, Vercken JB, et al. Trial of normobaric and hyperbaric oxygen for acute carbon monoxide intoxication. Lancet. 1989;2(8660):414-419. [pmid: 2569600].
8 Scheinkestel CD, Bailey M, Myles PS, Jones K, Cooper DJ, Millar IL, et al. Hyperbaric or normobaric oxygen for acute carbon monoxide poisoning: a randomized controlled clinical trial. Undersea & Hyperbaric Medicine. 2000;27(3):163-164. [pmid: 11191163].
9 Thom SR, Taber RL, Mendiguren II, Clark JM, Hardy KR, Fisher AB. Delayed neuropsychologic sequelae after carbon monoxide poisoning: prevention by treatment with hyperbaric oxygen. Annals of Emergency Medicine. 1995;25(4):474-480. [pmid: 7710151].
10 Weaver LK, Hopkins RO, Chan KJ, Churchill S, Elliott CG, Clemmer TP, et al. Hyperbaric oxygen for acute carbon monoxide poisoning. New England Journal of Medicine. 2002;347(14):1057-1067. [pmid: 12362006].
11 Juurlink DN, Buckley NA, Stanbrook MB, Isbister GK, Bennett M, McGuigan MA. Hyperbaric oxygen for carbon monoxide poisoning.[update of Cochrane Database Syst Rev. 2000;(2):CD002041; PMID: 10796853]. Cochrane Database of Systematic Reviews. 2005;(1):CD002041. [pmid: 15674890].
12 Saunders PJ. Hyperbaric oxygen therapy in the management of carbon monoxide poisoning, osteoradionecrosis, burns, skin grafts, and crush injury. International Journal of Technology Assessment in Health Care. 2003;(3):521-525. [pmid: 12962338].
13 Tibbles PM, Edelsberg JS. Hyperbaric-oxygen therapy. New England Journal of Medicine. 1996;334(25):1642-1648. [pmid: 8628361].
14 Wang C, Lau J. Hyperbaric oxygen therapy in treatment of hypoxic wounds. 2001. http://new.cms.hhs.gov/mcd/viewtechassess.asp?id=37.
15 Medical Services Advisory Committee (MSAC) application 1054. Hyperbaric oxygen therapy for the treatment of non-healing, refractory wounds in non-diabetic patients and refractory soft tissue radiation injuries. http://www.msac.gov.au/. 2003.
16 The Ontario health technology literature review. Hyperbaric oxygen therapy for non-healing ulcers in diabetes mellitus. http://www.health.gov.on.ca/english/providers/program/mas/tech/reviews/pdf/rev_hypox_081105.pdf. 2005.
17 Lawson R. Hyperbaric oxygen for osteomyelitis. 2003. http://www.signpoststeer.org. Report No.: 18.
18 Bennett MH, Feldmeier J, Hampson N, Smee R, Milross C. Hyperbaric oxygen therapy for late radiation tissue injury. Cochrane Database of Systematic Reviews. 2005;(4).
19 Denton AS, Maher EJ. Interventions for the physical aspects of sexual dysfunction in women following pelvic radiotherapy. Cochrane Database of Systematic Reviews. 2005;(4).
20 Feldmeier JJ, Hampson NB. A systematic review of the literature reporting the application of hyperbaric oxygen prevention and treatment of delayed radiation injuries: an evidence based approach. Undersea & Hyperbaric Medicine. 2002;29(1):4-30. [pmid: 12507182].
21 Johnston MJ, Robertson GM, Frizelle FA. Management of late complications of pelvic radiation in the rectum and anus: a review. Diseases of the Colon & Rectum. 2003;46(2):247-259. [pmid: 12576899].
22 Pasquier D, Hoelscher T, Schmutz J, Dische S, Mathieu D, Baumann M, et al. Hyperbaric oxygen therapy in the treatment of radio-induced lesions in normal tissues: a literature review. Radiotherapy & Oncology. 2004;72(1):1-13. [pmid: 15236869].
23 RoecklWiedmann I, Bennett M, Kranke P. Systematic review of hyperbaric oxygen in the management of chronic wounds. British Journal of Surgery. 2005;92(1):24-32. [pmid: 15635604].
24 Wang C, Schwaitzberg S, Berliner E, Zarin DA, Lau J. Hyperbaric oxygen for treating wounds: a systematic review of the literature. Archives of Surgery. 2003;138(3):272-279. discussion 280. [pmid: 12611573].
25 Abidia A, Laden G, Kuhan G, Johnson BF, Wilkinson AR, Renwick PM, et al. The role of hyperbaric oxygen therapy in ischaemic diabetic lower extremity ulcers: a double-blind randomised-controlled trial. European Journal of Vascular & Endovascular Surgery. 2003;25(6):513-518. [pmid: 12787692].
26 Annane D, Depondt J, Aubert P, Villart M, Gehanno P, Gajdos P, et al. Hyperbaric oxygen therapy for radionecrosis of the jaw: a randomized, placebo-controlled, double-blind trial from the ORN96 study group. Journal of Clinical Oncology. 2004;22(24):4893-4900. [pmid: 15520052].
27 Kessler L, Bilbault P, Ortega F, Grasso C, Passemard R, Stephan D, et al. Hyperbaric oxygenation accelerates the healing rate of nonischemic chronic diabetic foot ulcers: a prospective randomized study. Diabetes Care. 2003;26(8):2378-2382. [pmid: 12882865].
28 Bennett M, Jepson N, Lehm J. Hyperbaric oxygen therapy for acute coronary syndrome. Cochrane Database of Systematic Reviews. 2005;2:CD004818. [pmid: 15846734].
29 Dekleva M, Neskovic A, Vlahovic A, Putnikovic B, Beleslin B, Ostojic M. Adjunctive effect of hyperbaric oxygen treatment after thrombolysis on left ventricular function in patients with acute myocardial infarction. American Heart Journal. 2004;148(4):E14. [pmid: 15459609].
30 Vlahovic A, Neskovic AN, Dekleva M, Putnikovic B, Popovic ZB, Otasevic P, et al. Hyperbaric oxygen treatment does not affect left ventricular chamber stiffness after myocardial infarction treated with thrombolysis. American Heart Journal. 2004;148(1):E1. [pmid: 15215810].
31 McDonagh M, Carson S, Ash J, et al. Hyperbaric oxygen therapy for brain injury, cerebral palsy, and stroke. Evidence Report/Technology Assessment No.85. AHRQ publication No. 04-E003. Rockville, MD. Agency for Healthcare Research and Quality. 2003.
32 Bennett MH, Wasiak J, Schnabel A, Kranke P, French C. Hyperbaric oxygen therapy for acute ischaemic stroke. Cochrane Database of Systematic Reviews. 2005;(4).
33 Alternative Therapy Evaluation Committee for the Insurance Corporation of British Columbia. A review of the scientific evidence on the treatment of traumatic brain injuries and strokes with hyperbaric oxygen. Brain Injury. 2003;17(3):225-236. [pmid: 12623499].
34 Bennett MH, Trytko B, Jonker B. Hyperbaric oxygen therapy for the adjunctive treatment of traumatic brain injury. Cochrane Database of Systematic Reviews. 2004;(4):CD004609. [pmid: 15495120].
35 McDonagh M, Carson S, Ash J, Russman BS, Stavri PZ, Krages KP, et al. Hyperbaric oxygen therapy for brain injury, cerebral palsy, and stroke. Evidence Report: Technology Assessment (Summary). 2003;(85):1-6.
36 Bennett M, Feldmeier J, Smee R, Milross C. Hyperbaric oxygenation for tumour sensitisation to radiotherapy. Cochrane Database of Systematic Reviews. 2005;(4).
37 Widmark A, Flodgren P, Damber JE, Hellsten S, CavallinStahl E. A systematic overview of radiation therapy effects in urinary bladder cancer. Acta Oncologica. 2003;42(5–6):567-581. [pmid: 14596515].
38 Eftedal OS, Lydersen S, Helde G, White L, Brubakk AO, Stovner LJ. A randomized, double blind study of the prophylactic effect of hyperbaric oxygen therapy on migraine. Cephalalgia. 2004;24(8):639-644. [pmid: 15265052].
39 Nilsson Remahl AI, Ansjon R, Lind F, Waldenlind E. Hyperbaric oxygen treatment of active cluster headache: a double-blind placebo-controlled cross-over study. Cephalalgia. 2002;22(9):730-739. [pmid: 12421159].
40 Bennett MH, Kertesz T, Yeung P. Hyperbaric oxygen for idiopathic sudden sensorineural hearing loss and tinnitus. Cochrane Database of Systematic Reviews. 2005;(1):CD004739. [pmid: 15674964].
41 Topuz E, Yigit O, Cinar U, Seven H. Should hyperbaric oxygen be added to treatment in idiopathic sudden sensorineural hearing loss?. European Archives of Oto-Rhino-Laryngology. 2004;261(7):393-396. [pmid: 14586625].
42 Vavrina J, Muller W. Therapeutic effect of hyperbaric oxygenation in acute acoustic trauma. Revue de Laryngologie Otologie Rhinologie. 1995;116(5):377-380. [pmid: 8677379].
43 Kleijnen J, Knipschild P. Hyperbaric oxygen for multiple sclerosis. Review of controlled trials. Acta Neurologica Scandinavica. May. 1995;91(5):330-334. [pmid: 7639061].
44 Bennett M, Heard R. Hyperbaric oxygen therapy for multiple sclerosis. Cochrane Database of Systematic Reviews. 2005;(4).
45 Monks J. Interpretation of subjective measures in a clinical trial of hyperbaric oxygen therapy for multiple sclerosis. Journal of Psychosomatic Research. 1988;32(4–5):365-372. [pmid: 3070011].
46 Wood J, Stell R, Unsworth I, Lance JW, Skuse N. A double-blind trial of hyperbaric oxygen in the treatment of multiple sclerosis. Medical Journal of Australia. 1985;143(6):238-240. [pmid: 3897808].
47 Kranke P, Bennett M, RoecklWiedmann I, Debus S. Hyperbaric oxygen therapy for chronic wounds. Cochrane Database of Systematic Reviews. 2004;(2):CD004123. [pmid: 15106239].
48 RoecklWiedmann I, Bennett M, Kranke P. Systematic review of hyperbaric oxygen in the management of chronic wounds. British Journal of Surgery. 2005;92(1):24-32. [pmid: 15635604].
49 Bennett M, Best TM, Babul S, Taunton J, Lepawsky M. Hyperbaric oxygen therapy for delayed onset muscle soreness and closed soft tissue injury. Cochrane Database of Systematic Reviews. 2005;(4).
50 Villanueva E, Bennett MH, Wasiak J, Lehm JP. Hyperbaric oxygen therapy for thermal burns. Cochrane Database of Systematic Reviews. 2004;(3):CD004727. [pmid: 15266540].
51 Liu HW, Pang FC, Lee KY. The Hospital Authority Healthcare Technology Assessment Report. Hyperbaric oxygen and avascular necrosis of bone. Report HTA 13. 2003.
52 Bojic L, Kovacevic H, Andric D, Romanovic D, Petri NM. Hyperbaric oxygen dose of choice in the treatment of glaucoma. Arhiv Za Higijenu Rada i Toksikologiju. 1993;44(3):239-247. [pmid: 8311697].
53 Vingolo EM, Pelaia P, Forte R, Rocco M, Giusti C, Rispoli E. Does hyperbaric oxygen (HBO) delivery rescue retinal photoreceptors in retinitis pigmentosa?. Documenta Ophthalmologica. 1998;97(1):33-39. 99. [pmid: 10710240].
54 Recupero SM, Cruciani F, Picardo V, Sposato PA, Tamanti N, Abdolrahimzadeh S. Hyperbaric oxygen therapy in the treatment of secondary keratoendotheliosis. Annals of Ophthalmology. 1992;24(12):448-452. [pmid: 1485740].
55 Handbook on hyperbaric medicine. Berlin; Heidelberg; NewYork. Springer-Verlag. 1996.
56 Hyperbaric medicine practice. Flagstaff, AZ. Best Publishing Company. 1999. Second ed.
57 Alex J, Laden G, Cale AR, Bennett S, Flowers K, Madden L, Gardiner E, McCollum PT, Griffin SC. Pretreatment with hyperbaric oxygen and its effect on neuropsychometric dysfunction and systemic inflammatory response after cardiopulmonary bypass: a prospective randomized double-blind trial. J Thorac Cardiovasc Surg. 2005;130(6):1623-1630. [pmid: 16308008].