# Appendices

A MEDLINE search strategy

B Cochrane clinical trials search strategy

C MEDLINE review search strategy

D Evidence Tables

E References of included case reports