# References and Included Studies

1 Dowson D. New joints for the Millennium: wear control in total replacement hip joints. Proc Inst Mech Eng [H]. 2001;215(4):335-58.
2 Ethgen O, Bruyere O, Richy F, Dardennes C, Reginster JY. Health-related quality of life in total hip and total knee arthroplasty: a qualitative and systematic review of the literature. J Bone Joint Surg Am. 2004;86(5):963-74. [pmid: 15118039].
3 Mahomed NN, Barrett JA, Katz JN, Phillips CB, Losina E, Lew RA, Guadagnoli E, Harris WH, Poss R, Baron JA. Rates and outcomes of primary and revision total hip replacement in the United States medicare population. J Bone Joint Surg Am. Jan. 2003;85-A(1):27-32. [pmid: 12533568].
4 HCUPnet: a tool for identifying, tracking, and analyzing national hospital statistics. [Web site]. Rockville (MD). Agency for Healthcare Research and Quality. 2004. 2004 Sep 30. [various]. Available: http://hcup.ahrq.gov/HCUPnet.asp.
5 Kurtz S, Mowat F, Ong K, Chan N, Lau E, Halpern M. Prevalence of primary and revision total hip and knee arthroplasty in the United States from 1990 through 2002. J Bone Joint Surg Am. 2005;87(7):1487-97. [pmid: 15995115].
6 Hyer R. Number of revision total knee arthroplasties predicted to soar by 2030. [internet]. New York (NY). WebMD. Mar. 27. 2006 Apr 6. 2006:2. Available:http://www.medscape.com/viewarticle/528643.
7 Paprosky WG, Martin EL. Removal of well-fixed femoral and acetabular components. Am J Orthop. Aug. 2002;31(8):476-8. [pmid: 12216971].
8 Jones RE. Modular revision stems in total hip arthroplasty. Clin Orthop Relat Res. Mar. 2004;(420):142-7. [pmid: 15057090].
9 Burstein G, Yoon P, Saleh KJ. Component removal in revision total hip arthroplasty. Clin Orthop Relat Res. Mar. 2004;(420):48-54. [pmid: 15057078].
10 Glassman AH. Exposure for revision: total hip replacement. Clin Orthop Relat Res. Mar. 2004;(420):39-47. [pmid: 15057077].
11 Iorio R, Healy WL, Richards JA. Comparison of the hospital cost of primary and revision total hip arthroplasty after cost containment. Orthopedics. Feb. 1999;22(2):185-9. [pmid: 10037332].
12 Ong BC, Maurer SG, Aharonoff GB, Zuckerman JD, Koval KJ. Unipolar versus bipolar hemiarthroplasty: functional outcome after femoral neck fracture at a minimum of thirty-six months of follow-up. J Orthop Trauma. May. 2002;16(5):317-22. [pmid: 11972074].
13 Hay M, Gottschalk F. Cemented versus uncemented hip replacement for fracture of the hip. Disabil Rehabil. Sep. 30. 2005;27(18-19):1151-5. [pmid: 16278184].
14 Wilson V, Huo MH. Treatment of femoral neck fractures with prosthetic arthroplasty. Curr Opin Orthop. 2004;15(1):18-21.
15 Varley J, Parker MJ. Stability of hip hemiarthroplasties. Int Orthop. Oct. 2004;28(5):274-7. [pmid: 15316673].
16 Etienne G, Ragland P, Mont MA. Resurfacing arthroplasty for osteonecrosis: current opinions. Curr Opin Orthop. 2003;14(1):30-3.
17 Beaule PE. Surface arthroplasty of the hip: a review and current indications. Semin Arthroplasty. 2005;16(1):70-6.
18 Grecula MJ. Resurfacing arthroplasty in osteonecrosis of the hip. Orthop Clin North Am. Apr. 2005;36(2):231-42. [pmid: 15833461].
19 Vale L, Wyness L, McCormack K, McKenzie L, Brazzelli M, Stearns SC. A systematic review of the effectiveness and cost-effectiveness of metal-on-metal hip resurfacing arthroplasty for treatment of hip disease. Health Technol Assess. 2002;6(15):1-109. [pmid: 12137721].
20 Grigoris P, Roberts P, Panousis K, Bosch H. The evolution of hip resurfacing arthroplasty. Orthop Clin North Am. Apr. 2005;36(2):125-34. [pmid: 15833450].
21 Shimmin AJ, Bare J, Back DL. Complications associated with hip resurfacing arthroplasty. Orthop Clin North Am. Apr. 2005;36(2):187-93. [pmid: 15833456].
22 Huo MH, Gilbert NF. What's new in hip arthroplasty. J Bone Joint Surg Am. 2005;87(9 I):2133-46. [pmid: 16140830].
23 U.S. Food and Drug Administration. Office of Device Evaluation, Center for Devices and Radiological Health. Rockville, MD. Review of premarket approval application (PMA) for the Birmingham Hip Resurfacing (BHR) system. P040033. 2006. Mar. 2. 8 p.
24 U.S. Food and Drug Administration (FDA), Center for Devices and Radiological Health (CDRH). New device approval: Birmingham Hip resurfacing (BHR) system - P040033. [internet]. Rockville (MD). U.S. Food and Drug Administration (FDA). May. 9. 2006 May 10. 2006:3. Available: http://www.fda.gov/cdrh/mda/docs/p040033.html.
25 LaPorte DM, Mont MA, Hungerford DS. Proximally porous-coated ingrowth prostheses: limits of use. Orthopedics. Dec. 1999;22(12):1154-60. quiz 1161-2. [pmid: 10604809].
26 Crawford RW, Murray DW. Total hip replacement: indications for surgery and risk factors for failure. Ann Rheum Dis. Aug. 1997;56(8):455-7. [pmid: 9306866].
27 Parsons IM 4th, Sonnabend DH. What is the role of joint replacement surgery. Baillieres Best Pract Res Clin Rheumatol. Aug. 2004;18(4):557-72.
28 Sanchez-Sotelo J, Berry DJ. Epidemiology of instability after total hip replacement. Orthop Clin North Am. Oct. 2001;32(4):543-52. vii. [pmid: 11689368].
29 Soong M, Rubash HE, Macaulay W. Dislocation after total hip arthroplasty. J Am Acad Orthop Surg. Sep-Oct. 2004;12(5):314-21. [pmid: 15469226].
30 Huo MH, Brown BS. What's new in hip arthroplasty. J Bone Joint Surg Am. Sep. 2003;85-A(9):1852-64. [pmid: 12954856].
31 Sculco TP, Jordan LC. The mini-incision approach to total hip arthroplasty. Instr Course Lect. 2004;53:141-7. [pmid: 15116608].
32 Study reports complications for less invasive hip surgery. Clinica. Mar. 25. 2005;(1150):18.
33 Tanzer M. Two-incision total hip arthroplasty: techniques and pitfalls. Clin Orthop Relat Res. Dec. 2005;441:71-9. [pmid: 16330987].
34 Hungerford DS. Minimally invasive total hip arthroplasty: in opposition. J Arthroplasty. Jun. 2004;19(4 Suppl 1):81-2. [pmid: 15190556].
35 Pour AE, Parvizi J, Rothman RH. The outcomes of small-incision total hip arthroplasty using modifications of existing surgical approaches. Semin Arthroplasty. 2005;16(3):194-7.
36 Huo MH, Gilbert NF. Complications of minimal incision total hip arthroplasty. Curr Opin Orthop. 2005;16(1):18-20.
37 Weng HH, Fitzgerald J. Current issues in joint replacement surgery. Curr Opin Rheumatol. Mar. 2006;18(2):163-9. [pmid: 16462522].
38 National Institute for Clinical Excellence (NICE). Minimally invasive two-incision surgery for total hip replacement. London (UK). National Institute for Clinical Excellence (NICE). 2005. 2 p.
39 Allison C. Minimally invasive hip resurfacing. Ottawa (ON). Canadian Coordinating Office for Health Technology Assessment (CCOHTA). 2005. 4 p. Issues in Emerging Health Technologies; no. 65.
40 Single mini-incision hip replacement. London (UK). National Institute for Health and Clinical Excellence (NICE). 2006. Jan. Interventional procedure guidance; no. 152.
41 National Institute for Health and Clinical Excellence (NICE). Interventional procedures overview of single mini-incision hip replacement. London (UK). National Institute for Health and Clinical Excellence (NICE). 2005. 18 p.
42 Fick D, Nivbrant B. Minimally invasive surgical approaches for total hip arthroplasty in adults with osteoarthritis. Cochrane Database Syst Rev. 2004;(2). CD004798.
43 Specht LM, Koval KJ. Robotics and computer-assisted orthopaedic surgery. Bull Hosp Jt Dis. 2001-2002;60(3-4):168-72. [pmid: 12102405].
44 TARGET. [database online]. Plymouth Meeting (PA). ECRI. 2005. Oct. 2005 Oct 17. Computer-assisted navigation for total hip replacement. Available: http://www.ecri.org.
45 DiGioia AM 3rd, Blendea S, Jaramaz B, Levison TJ. Less invasive total hip arthroplasty using navigational tools. Instr Course Lect. 2004;53:157-64. [pmid: 15116610].
46 d'Augigne MR, Postel M. Functional results of hip arthroplasty with acrylic prostheses. J Bone Joint Surg Am. 1954;36A:451-75.
47 Garellick G, Herberts P, Malchau H. The value of clinical data scoring systems: are traditional hip scoring systems adequate to use in evaluation after total hip surgery. J Arthroplasty. Dec. 1999;14(8):1024-9. [pmid: 10614897].
48 Dawson J, Fitzpatrick R, Carr A, Murray D. Questionnaire on the perceptions of patients about total hip replacement. J Bone Joint Surg Br. Mar. 1996;78(2):185-90. [pmid: 8666621].
49 Fitzpatrick R, Norquist JM, Dawson J, Jenkinson C. Rasch scoring of outcomes of total hip replacement. J Clin Epidemiol. Jan. 2003;56(1):68-74. [pmid: 12589872].
50 Dawson J, Fitzpatrick R, Murray D, Carr A. Comparison of measures to assess outcomes in total hip replacement surgery. Qual Health Care. Jun. 1996;5(2):81-8. [pmid: 10158596].
51 Johanson NA, Charlson ME, Szatrowski TP, Ranawat CS. A self-administered hip-rating questionnaire for the assessment of outcome after total hip replacement. J Bone Joint Surg Am. Apr. 1992;74(4):587-97. [pmid: 1583054].
52 Katz JN, Phillips CB, Poss R, Harrast JJ, Fossel AH, Liang MH, Sledge CB. The validity and reliability of a Total Hip Arthroplasty Outcome Evaluation Questionnaire. J Bone Joint Surg Am. Oct. 1995;77(10):1528-34. [pmid: 7593061].
53 Saleh KJ, Kassim R, Yoon P, Vorlicky LN. Complications of total hip arthroplasty. Am J Orthop. Aug. 2002;31(8):485-8. [pmid: 12216974].
54 Conduah A, Lieberman JR. Venous thromboembolic prophylaxis after elective total hip arthroplasty. Clin Orthop Relat Res. Dec. 2005;441:274-84. [pmid: 16331015].
55 Geerts WH, Pineo GF, Heit JA, Bergqvist D, Lassen MR, Colwell CW, Ray JG. Prevention of venous thromboembolism: the Seventh ACCP Conference on Antithrombotic and Thrombolytic Therapy. Chest. Sep. 2004;126(3 Suppl):338S-400S. [pmid: 15383478].
56 Amstutz HC. Hip arthroplasty today and tomorrow. Orthopedics. Dec. 1987;10(12):1759-72. [pmid: 3324084].
57 Talmo CT, Bono JV. Preventing and managing intraoperative fractures and perforations in hip arthroplasty. Orthopedics. Sep. 2005;28(9 Suppl):s1085-8. [pmid: 16190042].
58 Neal B, Gray H, MacMahon S, Dunn L. Incidence of heterotopic bone formation after major hip surgery. ANZ J Surg. Nov. 2002;72(11):808-21. [pmid: 12437693].
59 Pakos EE, Pitouli EJ, Tsekeris PG, Papathanasopoulou V, Stafilas K, Xenakis TH. Prevention of heterotopic ossification in high-risk patients with total hip arthroplasty: The experience of a combined therapeutic protocol. Int Orthop. 2006;30(2):79-83. [pmid: 16482442].
60 Bourne RB, Mehin R. The dislocating hip: what to do, what to do. J Arthroplasty. Jun. 2004;19(4 Suppl 1):111-4. [pmid: 15190564].
61 DeWal H, Su E, DiCesare PE. Instability following total hip arthroplasty. Am J Orthop. Aug. 2003;32(8):377-82. [pmid: 12943337].
62 Dennis DA, Lynch CB. Stability advantages of a modular total hip system. Orthopedics. Sep. 2005;28(9 Suppl):s1049-52. [pmid: 16190034].
63 Mountney J, Garbuz DS, Greidanus NV, Masri BA, Duncan CP. Cementing constrained acetabular liners in revision hip replacement: clinical and laboratory observations. Instr Course Lect. 2004;53:131-40. [pmid: 15116607].
64 Lachiewicz PF, Kelley SS. The use of constrained components in total hip arthroplasty. J Am Acad Orthop Surg. Jul-Aug. 2002;10(4):233-8. [pmid: 15089072].
65 Heisel C, Silva M, Schmalzried TP. Bearing surface options for total hip replacement in young patients. Instr Course Lect. 2004;53:49-65. [pmid: 15116600].
66 Toms AD, Davidson D, Masri BA, Duncan CP. The management of peri-prosthetic infection in total joint arthroplasty. J Bone Joint Surg Br. Feb. 2006;88(2):149-55. [pmid: 16434514].
67 Swedish National Hip Arthroplasty Register. The Swedish National Hip Arthroplasty Register annual report 2004. Goteborg, Sweden. Swedish National Hip Arthroplasty Register. 2005. May. 74 p.
68 McKellop HA. Bearing surfaces in total hip replacements: state of the art and future developments. Instr Course Lect. 2001;50:165-79. [pmid: 11372311].
69 Bozic KJ, Ries MD. Wear and osteolysis in total hip arthroplasty. Semin Arthroplasty. 2005;16(2):142-52.
70 Murphy SB. Ceramic-ceramic bearings in THA: the new gold standard--in the affirmative. Orthopedics. Sep. 2002;25(9):933-4. [pmid: 12269415].
71 Bozic KJ, Jacobs JJ. Why the bearing surface matters: the problems caused by bearing surface wear. Semin Arthroplasty. 2003;14(2):57-68.
72 McCalden RW, Naudie DD, Yuan X, Bourne RB. Radiographic methods for the assessment of polyethylene wear after total hip arthroplasty. J Bone Joint Surg Am. Oct. 2005;87(10):2323-34. [pmid: 16203901].
73 Zichner LP, Willert HG. Comparison of alumina-polyethylene and metal-polyethylene in clinical trials. Clin Orthop Relat Res. Sep. 1992;(282):86-94. [pmid: 1516333].
74 Harris WH. Highly cross-linked, electron-beam-irradiated, melted polyethylene: some pros. Clin Orthop Relat Res. Dec. 2004;(429):63-7. [pmid: 15577467].
75 Santavirta S, Bohler M, Harris WH, Konttinen YT, Lappalainen R, Muratoglu O, Rieker C, Salzer M. Alternative materials to improve total hip replacement tribology. Acta Orthop Scand. Aug. 2003;74(4):380-8. [pmid: 14521286].
76 Dorr LD, Long WT, Sirianni L, Campana M, Wan Z. The argument for the use of Metasul as an articulation surface in total hip replacement. Clin Orthop Relat Res. Dec. 2004;(429):80-5. [pmid: 15577470].
77 Schweppe M. Paper 123: Low wear rates of ceramic-on-ceramic-bearing surfaces in total hip implants: a 12-year follow-up study. [internet]. New York (NY). Medscape Portals, Inc. 2003 Mar 7. 1999:2. Available: http://www.medscape.com/viewarticle/427302.
78 Boehler M, Knahr K, Plenk H Jr, Walter A, Salzer M, Schreiber V. Long-term results of uncemented alumina acetabular implants. J Bone Joint Surg Br. Jan. 1994;76(1):53-9. [pmid: 8300682].
79 Bizot P, Nizard R, Lerouge S, Prudhommeaux F, Sedel L. Ceramic/ceramic total hip arthroplasty. J Orthop Sci. 2000;5(6):622-7. [pmid: 11180930].
80 Sundfeldt M, Carlsson LV, Johansson CB, Thomsen P, Gretzer C. Aseptic loosening, not only a question of wear: a review of different theories. Acta Orthop. Apr. 2006;77(2):177-97. [pmid: 16752278].
81 Ritter MA, Faris GW. Alternative TKR bearing surfaces: the femur? You have got to be kidding. Orthopedics. Sep. 2003;26(9):967-980. [pmid: 14503769].
82 Clarke IC. Role of ceramic implants. Design and clinical success with total hip prosthetic ceramic-to-ceramic bearings. Clin Orthop Relat Res. Sep. 1992;(282):19-30. [pmid: 1516312].
83 Lindahl H, Garellick G, Regner H, Herberts P, Malchau H. Three hundred and twenty-one periprosthetic femoral fractures. J Bone Joint Surg Am. Jun. 2006;88(6):1215-22. [pmid: 16757753].
84 Clarke IC, Manaka M, Green DD, Williams P, Pezzotti G, Kim YH, Ries M, Sugano N, Sedel L, Delauney C, Nissan BB, Donaldson T, Gustafson GA. Current status of zirconia used in total hip implants. J Bone Joint Surg Am. 2003;85-A(Suppl 4):73-84. [pmid: 14652396].
85 Shah N, Porter M. Evolution of cemented stems. Orthopedics. Aug. 2005;28(8 Suppl):s819-25. [pmid: 16119721].
86 Dorr LD, Faugere MC, Mackel AM, Gruen TA, Bognar B, Malluche HH. Structural and cellular assessment of bone quality of proximal femur. Bone. May-Jun. 1993;14(3):231-42. [pmid: 8363862].
87 Rollins G. Total hip replacement deemed safe and effective in the very old. Rep Med Guidel Outcomes Res. Apr. 4. 2003;14(7):7-9.
88 Canadian Institute for Health Information. Canadian Joint Replacement Registry (CJRR) 2004 report: total hip and total knee replacements in Canada. Ottawa (ON). Canadian Institute for Health Information. 2004. 59 p.
89 Nizard RS, Sedel L, Christel P, Meunier A, Soudry M, Witvoet J. Ten-year survivorship of cemented ceramic-ceramic total hip prosthesis. Clin Orthop Relat Res. Sep. 1992;(282):53-63. [pmid: 1516329].
90 Winter M, Griss P, Scheller G, Moser T. Ten- to 14-year results of a ceramic hip prosthesis. Clin Orthop Relat Res. Sep. 1992;(282):73-80. [pmid: 1516331].
91 Annual report 2003: the Swedish National hip arthroplasty register. Goteborg, Sweden. Department of Orthopaedics, Sahlgrenska University Hospital. 2004. May. 1. 68 p.
92 Ilizaliturri VM Jr, Chaidez PA, Valero FS, Aguilera JM. Small incision total hip replacement by the lateral approach using standard instruments. Orthopedics. Apr. 2004;27(4):377-81. [pmid: 15101478].
93 Quintana JM, Azkarate J, Goenaga JI, Arostegui I, Beldarrain I, Villar JM. Evaluation of the appropriateness of hip joint replacement techniques. Int J Technol Assess Health Care. Winter. 2000;16(1):165-77. [pmid: 10815362].
94 Torisu T, Kaku N, Tumura H, Taira H, Tomari K. 3M integral bipolar cup system for dysplastic osteoarthritis. Clinical and radiographic review with five- to seven-year follow-up. J Bone Joint Surg Br. Aug. 2003;85(6):822-5. [pmid: 12931798].
95 Callaghan JJ, O'Rourke MR, Goetz DD, Lewallen DG, Johnston RC, Capello WN. Use of a constrained tripolar acetabular liner to treat intraoperative instability and postoperative dislocation after total hip arthroplasty: a review of our experience. Clin Orthop Relat Res. Dec. 2004;(429):117-23. [pmid: 15577475].
96 Sharkey PF, Shastri S, Teloken MA, Parvizi J, Hozack WJ, Rothman RH. Relationship between surgical volume and early outcomes of total hip arthroplasty: do results continue to get better?. J Arthroplasty. Sep. 2004;19(6):694-9. [pmid: 15343527].
97 Solomon DH, Losina E, Baron JA, Fossel AH, Guadagnoli E, Lingard EA, Miner A, Phillips CB, Katz JN. Contribution of hospital characteristics to the volume-outcome relationship: dislocation and infection following total hip replacement surgery. Arthritis Rheum. Sep. 2002;46(9):2436-44. [pmid: 12355492].
98 Katz JN, Losina E, Barrett J, Phillips CB, Mahomed NN, Lew RA, Guadagnoli E, Harris WH, Poss R, Baron JA. Association between hospital and surgeon procedure volume and outcomes of total hip replacement in the United States medicare population. J Bone Joint Surg Am. Nov. 2001;83-A(11):1622-9. [pmid: 11701783].
99 Fitzpatrick R, Shortall E, Sculpher M, Murray D, Morris R, Lodge M, Dawson J, Carr A, Britton A, Briggs A. Primary total hip replacement surgery: a systematic review of outcomes and modelling of cost-effectiveness associated with different prostheses. Health Technol Assess. 1998;2(20):1-64. [pmid: 10103353].
100 Engh CA, Sychterz CJ, Engh CA Jr. Conventional ultra-high molecular weight polyethylene: a gold standard of sorts. Instr Course Lect. 2005;54:183-7. [pmid: 15948445].
101 Jones DL, Westby MD, Greidanus N, Johanson NA, Krebs DE, Robbins L, Rooks DS, Brander V. Update on hip and knee arthroplasty: current state of evidence. Arthritis Care Res. Oct. 15. 2005;53(5):772-80.
102 Morscher EW. Failures and successes in total hip replacement - why good ideas may not work. Scand J Surg. 2003;92(2):113-20. [pmid: 12841550].
103 Cates CA, Huo MH. Alternative bearing surface in total hip arthroplasty. Curr Opin Orthop. 2005;16(1):21-4.
104 Sychterz CJ, Engh CA, Black J. Metal-on conventional polyethylene: strengths, limitations, and long-term data. Semin Arthroplasty. 2003;14(2):79-85.
105 McMinn DJ, Daniel J, Ziaee H. Controversial topics in orthopaedics: metal-on-metal. Ann R Coll Surg Engl. Nov. 2005;87(6):411-5. [pmid: 16402440].
106 Ries MD. Enhanced polyethylene implants: have we been there before?. Instr Course Lect. 2005;54:189-92. [pmid: 15948446].
107 Tuli R, Parvizi J. Alternative bearing surfaces in total hip arthroplasty. Expert Rev Med Devices. Jul. 2005;2(4):445-52. [pmid: 16293083].
108 Harris WH. Alternative bearing surfaces: crosslinked polyethylenes for total hip replacement. A review. Hip Int. 2003;13(3):127-32.
109 Dorr LD, Long WT. Metal-on-metal: articulations for the new millennium. Instr Course Lect. 2005;54:177-82. [pmid: 15948444].
110 Dumbleton JH, Manley MT. Metal-on-Metal total hip replacement: what does the literature say?. J Arthroplasty. Feb. 2005;20(2):174-88. [pmid: 15902856].
111 Clarke IC, Donaldson T, Bowsher JG, Nasser S, Takahashi T. Current concepts of metal-on-metal hip resurfacing. Orthop Clin North Am. Apr. 2005;36(2):143-62. [pmid: 15833452].
112 Grigoris P, Roberts P, Panousis K, Jin Z. Hip resurfacing arthroplasty: the evolution of contemporary designs. Proc Inst Mech Eng [H]. Feb. 2006;220(2):95-105.
113 Dearnley PA. A review of metallic, ceramic and surface-treated metals used for bearing surfaces in human joint replacements. Proc Inst Mech Eng [H]. 1999;213(2):107-35.
114 MacDonald SJ. Metal-on-metal total hip arthroplasty: the concerns. Clin Orthop Relat Res. Dec. 2004;(429):86-93. [pmid: 15577471].
115 Silva M, Heisel C, Schmalzried TP. Metal-on-metal total hip replacement. Clin Orthop Relat Res. Jan. 2005;(430):53-61. [pmid: 15662304].
116 Visuri TI, Pukkala E, Pulkkinen P, Paavolainen P. Cancer incidence and causes of death among total hip replacement patients: a review based on Nordic cohorts with a special emphasis on metal-on-metal bearings. Proc Inst Mech Eng [H]. Feb. 2006;220(2):399-407.
117 Silva M, Schmalzried TP. Metal-on-metal: history, basic science, and toxicity. Semin Arthroplasty. 2003;14(2):113-22.
118 Cuckler JM. The rationale for metal-on-metal total hip arthroplasty. Clin Orthop Relat Res. Dec. 2005;441:132-6. [pmid: 16330995].
119 Sedel L. Evolution of alumina-on-alumina implants: a review. Clin Orthop Relat Res. Oct. 2000;(379):48-54. [pmid: 11039792].
120 Kober S. Has the time come to ease the restrictions on ceramics?. [internet]. Orlando (FL). Slack, Inc. Feb. 2003 Mar 13. 2003:3. Available:http://www.slackinc.com.
121 O'Toole G, Walter WL, Zicat BA, Walter WK. Squeaking in ceramic-on-ceramic hips; incidence, causes and solutions [paper no 317]. American Academy of Orthopaedic Surgeons 2006 Annual Meeting. March 22-26, 2006. Chicago (IL). Mar. 23. 2006:2. Also available: http://www2.aaos.org/anmeet2005/podium/podium.cfm?Prevent=317.
122 Hamadouche M, Meunier A, Nich C, Sedel L. Ceramic-on-ceramic articulation in total hip arthroplasty: history, basic science, tribological properties. Semin Arthroplasty. 2003;14(2):93-103.
123 D'Antonio J, Capello W, Manley M, Naughton M, Sutton K. Alumina ceramic bearings for total hip arthroplasty: five-year results of a prospective randomized study. Clin Orthop Relat Res. Jul. 2005;(436):164-71. [pmid: 15995436].
124 Innovative ‘ceramic on metal’ hip replacements to undergo clinical trials. [internet]. Swindon UK. Engineering and Physical Sciences Research Center (EPSRC). Aug. 19. 2005 Apr 11. 2004:4. Available: http://www.epsrc.ac.uk/Content/PressReleases/CeramicOnMetalHipReplacements.htm.
125 Impliant Limited. Start-up Impliant initiates clinical trial for new joint implant. [internet]. Rishon Le-Zion, Israel. Globes Online. Jul. 7. 2005 Apr 8. 2004:1. Available: http://www.globes.co.il/serveen/globes.
126 Dumbleton J, Manley MT. Hydroxyapatite-coated prostheses in total hip and knee arthroplasty. J Bone Joint Surg Am. Nov. 2004;86-A(11):2526-40. [pmid: 15523030].
127 Geesink RG. Osteoconductive coatings for total joint arthroplasty. Clin Orthop Relat Res. Feb. 2002;(395):53-65. [pmid: 11937866].
128 Cook SD, Barrack RL, Patron LP, Salkeld SL. Osteoinductive agents in reconstructive hip surgery: a look forward. Clin Orthop Relat Res. Dec. 2003;(417):195-202. [pmid: 14646717].
129 Gross AE. The role of polymethylmethacrylate bone cement in revision arthroplasty of the hip. Orthop Clin North Am. Jan. 2005;36(1):49-54. vi. [pmid: 15542122].
130 Parker MJ, Gurusamy K. Arthroplasties (with and without bone cement) for proximal femoral fractures in adults. Cochrane Database Syst Rev. 2004;(2). CD001706.
131 Ni GX, Lu WW, Chiu KY, Fong DY. Cemented or uncemented femoral component in primary total hip replacement? A review from a clinical and radiological perspective. J Orthop Surg. Apr. 2005;13(1):96-105.
132 Ries MD. Complications in primary total hip arthroplasty: avoidance and management: wear. Instr Course Lect. 2003;52:257-65. [pmid: 12690853].
133 Parvizi J, Morrey BF. Bipolar hip arthroplasty as a salvage treatment for instability of the hip. J Bone Joint Surg Am. Aug. 2000;82-A(8):1132-9. [pmid: 10954103].
134 National Institute for Clinical Excellence. Guidance on the selection of prostheses for primary total hip replacement. London (UK). National Institute for Clinical Excellence. 2000. Apr. 1. 12 p. (Technology appraisal guidance; no 2). Also available: http://www.nice.org.uk.
135 Illgen R II, Shanbhag A, Jacobs J. Periprosthetic osteolysis: pathophysiology and medical management. Semin Arthroplasty. 2002;13(4):238-54.
136 Eskelinen A, Remes V, Helenius I, Pulkkinen P, Nevalainen J, Paavolainen P. Total hip arthroplasty for primary osteoarthrosis in younger patients in the Finnish arthroplasty register. 4,661 primary replacements followed for 0-22 years. Acta Orthop. Feb. 2005;76(1):28-41. [pmid: 15788305].
137 Helse-Bergen HF. The Norwegian Arthroplasty Register 2005 report. Norway. Norwegian Arthroplasty Register, Norwegian Cruciate Ligament Register, Norwegian Hip Fracture Register. 2005. 51 p.
138 Strash WW, Berardo P. Radiographic assessment of the hindfoot and ankle. Clin Podiatr Med Surg. Jul. 2004;21(3):295-304. v. [pmid: 15246139].
139 Wu CC, Shih CH. Cementless ceramic total hip arthroplasty: a 5 to 16 year follow-up. Changgeng Yi Xue Za Zhi. Sep. 1998;21(3):300-5. [pmid: 9849011].
140 McAuley JP, Szuszczewicz ES, Young A, Engh CA Sr. Total hip arthroplasty in patients 50 years and younger. Clin Orthop Relat Res. Jan. 2004;(418):119-25. [pmid: 15043102].
141 Toms AD, Barker RL, Jones RS, Kuiper JH. Impaction bone-grafting in revision joint replacement surgery. J Bone Joint Surg Am. Sep. 2004;86-A(9):2050-60. [pmid: 15342772].
142 Berry DJ. Antiprotrusio cages for acetabular revision. Clin Orthop Relat Res. Mar. 2004;(420):106-12. [pmid: 15057085].
143 Cuckler JM, Moore KD. The role of acetabular cages in revision. Orthopedics. Aug. 2004;27(8):831-846. [pmid: 15369003].
144 Gross AE, Goodman S. The current role of structural grafts and cages in revision arthroplasty of the hip. Clin Orthop Relat Res. Dec. 2004;(429):193-200. [pmid: 15577487].
145 Phillips CB, Barrett JA, Losina E, Mahomed NN, Lingard EA, Guadagnoli E, Baron JA, Harris WH, Poss R, Katz JN. Incidence rates of dislocation, pulmonary embolism, and deep infection during the first six months after elective total hip replacement. J Bone Joint Surg Am. Jan. 2003;85-A(1):20-6. [pmid: 12533567].
146 Aamodt A, Nordsletten L, Havelin LI, Indrekvam K, Utvag SE, Hviding K. Documentation of hip prostheses used in Norway: a critical review of the literature from 1996--2000. Acta Orthop Scand. Dec. 2004;75(6):663-76. [pmid: 15762255].
147 ECRI. Prostheses, joint, hip. Plymouth Meeting (PA). ECRI. 2005. Apr. 61 p. Healthcare product comparison system; no. 04/05.