# Ongoing or Planned Clinical Trials of THR

Table 8 presents a list of randomized controlled trials of THR that are currently being conducted, are being planned, or were recently completed. These trials were identified by searching Controlled Clinical Trials. The trials are organized according to the major clinical question being addressed.

Table 8 Ongoing or Planned Randomized Controlled Trials of THR

Name of Trial | Target Enrollment | Anticipated Start and Finish Dates | Outcomes and Other Study Information | Follow-up Period | Sponsor | Location
Minimally Invasive Surgery
1. Minimally invasive surgery in total hip arthroplasty: the 2-incision technique versus conventional total hip arthroplasty. | 110 | 11/2005 to 01/2009 | Functional effectiveness measured by Harris Hip Score | 12 months | Zimmer (USA) | Netherlands
2 Does a small incision at the time of total hip replacement confer an advantage to patients by comparison to a standard incision? | 128 | 9/2003 to 12/2005 | Blood loss, need for transfusion, length of hospital stay, pain measurement | 6 months | Royal Devon & Exeter Healthcare NHS Trust | United Kingdom
3 Minimally invasive surgery of the hip versus standard approach | 40 | 6/2003 to 12/2010 | Length of hospital stay | Not reported | Zimmer | Canada
4 Randomized, prospective, post-market surveillance study comparing the outcomes of minimally invasive and conventional surgical procedures in subjects requiring primary total hip arthroplasty for osteoarthritis | Not reported | Not yet recruiting | Post-operative rehabilitation and mobilization | Not reported | DePuy International | Not reported
5 Single versus dual incision minimally invasive hip arthroplasty | Not reported | Not reported | Not reported | Not reported | Perth Orthopaedic Institute | Australia
Hip Resurfacing or Hemiarthroplasty versus Total Hip Replacement
1. Comparison of hip resurfacing to large femoral head total hip arthroplasty | 108 | Recruiting | Quality of life between patients with Durom (Zimmer) hip resurfacing versus those with THR using a large-head, metal-on-metal articulation | 24 months | University of British Columbia | Canada
2 A comparison of two total hip replacements: hip resurfacing system (ReCap from Biomet Merck) versus Mallory-Head/Exeter | 50 | 1/2005 to 1/2014 | Metal ion release in urine, inflammatory response in plasma correlated with metal ions in urine, bone mineral density | 24 months | University of Aarhus, Denmark Biomet Merck Aps | Denmark
3 Prospective randomized study comparing the Furlong uncemented total hip replacement with the Birmingham resurfacing prosthesis. | 100 | 9/2000 to 9/2005 Data collection ongoing | Harris hip score and prosthesis longevity | Not reported | Not reported | United Kingdom
4 A randomized prospective trial comparing unipolar hemiarthroplasty, bipolar hemiarthroplasty and total hip replacement in the treatment of displaced intracapsular femoral neck fractures. | Not reported | 6/2003 to 6/2008 | Mortality, pain at each follow-up, mobility and walking aids, complications | Not reported | East Sussex Hospitals NHS Trust | United Kingdom
5 Primary ceramic-on-ceramic total hip replacement versus metal-on-metal hip resurfacing in young active patients | 400 | Recruiting | Functional results and fastness of revalidation | Not reported | University Hospital Ghent | Belgium
Method of Fixation: Cemented and Noncemented, Surface Material
1. Optimum socket fixation at total hip replacement | Not reported | 11/1999 to 11/2004 Data collection ongoing | Cemented versus uncemented socket longevity determined by radiostereometry, implant loosening, implant migration, and excessive wear | Not reported | Royal Devon and Exeter NHS Trust R D & E Healthcare NHS Trust | United Kingdom
2 Is a pre-cemented cup an improvement on a cemented cup? | 40 | 11/2003 to 11/2013 | Migration and wear of acetabular component. Objective measures. | Not reported | Robert Jones and Agnes Hunt Orthopaedic Hospital NHS R&D Support Funding | United Kingdom
3 Safety of non-delayed weight bearing after total hip replacement with noncemented Zimmer fiber metal taper stem | 33 | 5/2003 to 6/2007 | Effect of immediate weight bearing on femoral stem subsidence on X-ray, return to work, walking without assistive device | 24 months | Vanderbilt University Zimmer | United States
4 A comparison of two surface materials (Tantalum versus Titanium Fiber Mesh) of acetabular components in hip arthroplasty | 50 | 9/2004 to 1/2009 | Acetabular component migration evaluated by radiostereometry | 24 months | University of Aarhus Zimmer | Denmark
5 A randomized prospective trial comparing modular and straight neck femoral components in fully hydroxyapatite coated (HAC) uncemented primary total hip replacement | Not reported | 4/2002 to 4/2007 | Better functional outcome and improved survival of the prosthesis | Not reported | East Sussex Hospitals NHS Trust | United Kingdom
Bearing Surfaces
1. Ceramic-on-ceramic hip study (compared with metal-on-metal) | 240 | Recruiting | Success / Failure Harris Hip, Complications | Not reported | DePuy Orthopaedics | United States
2 Prospective clinical evaluation of three prosthesis: ReCap, M2a-Magnum, and C2a-Taper | Not reported | Not yet recruiting | ReCap is a femoral resurfacing system, M2a-Magnum is a large metal-on-metal articulation, and C2a-Taper is a ceramic-on-ceramic acetabular system (all made by Biomet). | Not reported | Frederiksberg University Hospital | Denmark
3 Improving the bearing surface in total hip replacement: the use of oxidized Zirconium and highly cross-linked polyethylene – a randomized controlled trial | 200 | 9/2004 to 9/2009 | THR using either cobalt chrome or oxinium femoral heads and either standard or highly cross-linked polyethylene liners. Radiographic wear, measuring linear and volumetric wear | Not reported | University College London Hospitals NHS Trust Discretionary grant from Smith & Nephew to fund salary of MD student | United Kingdom
4 Metal-on-metal versus ceramic-on-metal hip replacement | 384 | Recruiting | Success / Failure Harris Hip, Complications | Not reported | DePuy Orthopaedics | United States
5 A multi-center, randomized, parallel group, controlled study to compare the performance of the Future Hip against three currently used implants in total hip replacement. | Not reported | Recruiting | Evaluate clinical and radiological performance | Not reported | DePuy Orthopaedics | Austria
6 A prospective, randomized, controlled, single center, blinded study of the wear characteristics of two polyethylene bearing surfaces, Enduron vs. Marathon | No longer recruiting | Not reported | Evaluate the linear and volumetric wear of the two polyethylene materials | Not reported | DePuy International | United States
Revision Surgery
1. A randomized multi-center controlled trial of large diameter versus conventional diameter femoral heads for the prevention of post revision arthroplasty dislocation | 400 | Recruiting | Dislocation rate, polyethylene wear, functional and quality of life measures, radiographic findings, rate of re-revision | 24 months | University of British Columbia | Canada
2 A randomized controlled trial comparing a titanium to a cobalt chrome femoral stem in revision hip arthroplasty: a pilot study | Not reported | 10/2001 to 12/2010 | Solution Stem (cobalt chrome, a DePuy product) without a hydroxyapatite coating versus the Restoration hip stem (a Stryker product) made of titanium alloy with a roughened surface and allows for a hydroxyapatite coating. Bone mineral density, rates of osteolysis/radiolucent lines on radiographs, Harris Hip Score, rate of revision. | Not reported | Ottawa Health Research Institute Stryker | Canada