# Hip Replacement Revision

No artificial device can be expected to last forever. Any prosthesis will fail if the patient survives long enough. When prostheses fail, revision surgery is usually required. Causes of failure include breakage, dislocation, loosening, infection, or the joint simply wearing out. Factors contributing to these processes are discussed in the relevant sections of this report. Revision rates are commonly believed to vary depending on the type of implant, its fixation method, surgeon experience, and patient characteristics. The individual contributions of each of these factors to revision rates cannot be determined because of the large number of factors involved and the complexity of relationships between them. For the same reason, revision rates vary widely. The U.K. National Institute for Clinical Excellence has set a revision rate of 10% or less over 10 years as its benchmark for treatment success.(134) The Swedish National Hip Arthroplasty Register reports an overall ten-year survival rate of 92.5% for the observation period of 1992 to 2003.(91)

Revision surgery is considerably more difficult than primary THR. The surgeon must remove existing implants as well as cement, screws, cables, wires and plates.(10) Then the new prosthetic components are implanted along with any necessary additional fixation or reinforcement hardware that may be required. In cases of significant bone loss, which is common, structural allografts must be performed. During these time-consuming procedures, the surrounding soft tissues and musculature must be preserved as much as possible in order to preserve blood supply to the bone, stability against dislocation, and ability to walk.(10) Revision THR also has a higher rate of intraoperative fractures than primary THR.(57)

Aseptic loosening of the implants is the most common reason for revision surgery.(22,135) The Swedish National Hip Arthroplasty Register Annual Report for 2004 reported that overall 73% of revisions between 1979 and 2004 were due to aseptic loosening.(67) Dislocation and deep infection were next, each with about 8%. For revisions performed within the first three years after implantation, aseptic loosening was responsible for 48% of revisions, deep infection for 19%, and dislocation for 17.5% of revisions.. The Finnish Arthroplasty Register(136), the Norwegian Arthroplasty Register(137), and the Canadian Joint Replacement Registry(138) all list aseptic loosening as the leading cause for revision surgery (82%, 68%, and 55%, respectively).

Revision rates are thought to be affected by hip design, materials and fixation methods, as well as patient age and activity level. Because wear and loosening are progressive processes, revision rates increase with length of followup, regardless of the hip design, materials, or fixation methods. This can make comparisons of different models and designs of prosthetic hips difficult, because newer models do not have sufficient duration of followup to ascertain their long-term revision rates. Patient characteristics may also differ for studies of newer vs. older models.

Table 7 Reported Hip Revision Rates Under various Conditions

Implant Material | Revision Rate | Follow-up Time | Reference Source
Cementless Ceramic-on-Ceramic | 5.9% | Mean: 144 Months | Boehler et al., 1994(78)
Cementless Ceramic-on-Ceramic | 25% | Mean: 9.8 Years, Range: 5 to 16 | Wu and Shih, 1998(139)
Cementless Ceramic-on-Ceramic | 25% | 10-14 Years | Winter et al., 1992(90)
Cemented Ceramic-on-Ceramic | 12.8%, with 20.8% of patients lost to follow-up | 10 Years | Nizard et al., 1992(89)
Cemented Ceramic-on-Ceramic | 17% 30% 15% Among patients under 50 | 10 Years 15 Years 15 Years | Bizot et al., 2000(79)
Porous-coated metal stems, metal-on-metal, patients aged 50 or younger | 11% 40% | 10 Years 15 Years | McAulet et al., 2004(140)

Aseptic loosening due to osteolysis also presents the greatest challenges to successful revision. Loss of bone around the previous implant may mean that there is insufficient bone left to support a new prosthesis. This can lead to bone breakage during or shortly after the procedure,(30) or poor contact between implant and bone. Two hip reconstruction techniques are available to restore bone stock: impaction bone-grafting and structural allografts.(141)

In impaction bone-grafting, crushed or morselized bone (usually fresh-frozen cadaveric bone) is compacted against host bone.(141) Ideally, this will achieve a stable implant and subsequently allow restoration of living bone through bone ingrowth. Cement can be used in the construction of the graft, but must not interfere with the host/graft interface, as this would impair the host's bone cells ability to penetrate and remodel graft bone.(129) Combining the morselized bone with a very large (“jumbo”) cementless cup seems to be a viable option for acetabular revisions when sufficient pelvic bone is still present to support the cup.(30) The large cup size provides more contact with host bone to increase cup stability.(142)

Major acetabular bone deficiencies (bone loss involving more than 50% of the acetabulum) require a combination of structural allograft and pelvic reinforcement cages.(22,142-144) A structural allograft, obtained from acetabular bone, has the potential to restore bone stock to normal levels but must be protected by a cage. The procedure involves removal of the old acetabular prosthesis and debridement of the area. Then the acetabular allograft is trimmed to fit the defect. Cartilage is removed but subchondral bone is left intact. The graft is fixed to host bone using screws. The protective cage has flanges that extend over the ilium and into a slot formed in the ischium. The cage is placed over the graft and secured with bone screws via the ilium flange. A polyethylene cup prosthesis is cemented into the cage.

In many cases, an ingrown metal acetabular cup can be difficult or impossible to remove during revision. When this occurs, a new plastic liner can be cemented into the metal component.(63) The development of modular prosthetic components may, in some cases, make revision surgery easier in the future.

Outcomes after revision arthroplasty have been reported to be substantially worse than after primary arthroplasty.(3,141,145) This is largely due to poor quality of the remaining bone stock. Patients having revision surgery also tend to be older than those undergoing primary surgery. In addition, revision surgery takes longer and tends to involve more blood loss, in part because the older prosthesis must be removed before a new one can be implanted. Revision surgery is associated with increased rates of dislocation compared to primary hip replacement.(3,28,145)