# Difficulties in Interpreting Studies of THR

A guideline prepared by the U.K. National Institute for Clinical Excellence (NICE) in 2000 stated that evidence regarding THR is generally poor and difficult to interpret.(134) Few studies were of the best design, and few included long-term follow-up data. Other reviewers agree.(146)

NICE recommends follow-up times of at least 10 years for studies of THR.(134) This duration of followup would enable researchers to determine whether revision rates are lower than 10% at 10 years, which is NICE's benchmark for quality. Even when 10-year follow-up time is available, the prostheses used 10 years earlier may not be manufactured any longer, and incremental changes in design or technique over the intervening 10 years may affect the results of more recently performed procedures.(146) These factors limit interpretation of the results of even well-designed, long-term studies.

The design of the prosthesis is only one factor that may influence THR outcome. Patient characteristics, surgeon characteristics, surgical technique and quality of postsurgical care may also be important. While the effects of some of these factors have been investigated, the effect of interactions among and between factors is largely unknown.(134) Different studies are likely to have different patient inclusion criteria, different criteria defining success, and different criteria for determining whether revision surgery is necessary.(146) Charnley categories, patient age, sex, and activity level all influence the outcome of THR. Unless these factors are taken into account, the generalizability of the study cannot be determined, and the validity of comparing the results of one study to those of another is highly questionable.