# Background

Over the past 30 years, total hip replacement (THR) surgery, also known as total hip arthroplasty (THA), has become commonplace in the United States and throughout the world. It has been described as the greatest achievement in orthopedic surgery in the twentieth century.(1) Although no surgery is without risk, the utility of THR to relieve pain and restore function among patients with damaged or degenerated hips and chronic pain is well-accepted as indicated by the large number of procedures that take place in the United States each year.(2,3) In 2003 alone, 201,545 THR procedures and 34,688 revisions of THR were performed in the United States.(4) From 1990 through 2002, the number of THR procedures per 100,000 individuals in the United States increased by 46%, from approximately 45 to 66 per 100,000 individuals.(5) The same study reported a 60% increase in revisions of THR during the same time period. The rates of both primary and revision THR are expected to continue to increase. A recent report estimates that the annual number of THR revision surgeries will increase 137% by 2030.(6)

This horizon scan looks at some of the important issues facing orthopedic surgeons and other healthcare providers as they plan for the increasing utilization of THR. Areas of concern include:

- The selection of operative approaches (standard vs. minimally invasive or computer/robotic assisted)
- The design of the replacement prosthesis (metal-on-plastic, metal-on-metal, ceramic-on-ceramic, or some other combination)
- The surface coating of the prosthesis (untreated vs. treated)
- Cemented vs. uncemented fixation of the prosthesis.

## Total Hip Replacement

The THR procedure generally involves removal of the head of the femur and its replacement with a metal or ceramic prosthesis that fits into the remaining bone. The ball end of the artificial femur then fits into a cuplike socket (acetabular cup) that is installed in the patient's pelvis. Hip replacement can be unilateral (one hip) or bilateral (both hips). The longevity of currently available implants, the rate at which surgical revisions are needed to replace failed implants, and the ease with which implants can be replaced are primary concerns noted in the hip replacement literature. Artificial hips may work loose, break, wear out, or dislocate. Any of these occurrences may require revision surgery and replacement of part or all of the implant. Determining the primary reasons for revision surgery is difficult because some published studies report the reasons for revisions while others report only the number of revisions performed. Revision surgery tends to be more dangerous and less successful than primary surgery.(7-11)

The development of new implant materials has focused primarily on extending longevity in order to avoid revision. A secondary consideration is preserving the integrity of the remaining bone, to make future revision surgery easier.

## Hemiarthroplasty

Hemiarthroplasty refers to the replacement of only the femoral head and is most often performed in elderly patients who have sustained a displaced femoral neck fracture.(12) In this situation, the femoral head is at risk for avascular necrosis. Patients undergoing hemiarthroplasty have shown faster recovery of function and better function than patients treated only with internal fixation.(13) Some orthopedic surgeons have expressed a concern that hemiarthroplasty may not be the best option for active individuals expected to have long life expectancies.(14) Acetabular cartilage erosion from hemiarthroplasty leading to persistent pain and discomfort will occur if the device remains in place for longer periods. Therefore, younger more active individuals with a displaced femoral neck fracture may benefit more from THR than hemiarthroplasty.

In hemiarthroplasty the femoral head is usually replaced with a bipolar prosthesis. The bipolar prosthesis has an additional joint that allows movement to occur both at the prothesis-acetabular interface and within the prothesis. A proposed advantage of the doubled-jointed bipolar prothesis is a reduced risk of dislocation.(15) If pre-existing arthritis has damaged the acetabular cartilage, THR should be performed instead of hemiarthroplasty.

Hemi-resurfacing is similar to hemiarthroplasty, but only the surface of the femoral head is removed and replaced. Resurfacing arthroplasty involves minimal femoral head removal rather than resection of the entire femoral head and neck. The prosthesis forms a cap over the remaining femoral head and is secured with a stem inserted into the femoral head and neck bone. Hemi-resurfacing of the femoral head has a role in treating young patients with osteonecrosis of the hip in order to delay the need for THR in these patients.(16-18) The ideal candidate is less than 40 years old and has minimal acetabular cartilage damage. Patients receiving hemi-resurfacing arthroplasty rather than THR achieve higher activity levels but may experience more groin pain related to wear of the acetabular cartilage.

## Hip Resurfacing

Total hip resurfacing, involving resurfacing of both the femoral head and acetabular cup, is an alternative to THR. It is performed primarily on younger patients who would be expected to live long enough and remain active enough to wear out several THR devices.(19) Better stability and range of motion than THR has been cited as an advantage of this procedure.(20) With this procedure, the femoral head is preserved, reshaped, and capped with a metal shell. The socket is fitted with a prosthetic cup, as is the case with THR. This procedure can only be performed if the patient has sufficient healthy bone stock to support the resurfacing prosthetic. The ideal candidate for this procedure is less than 60 years old, has normal proximal femoral bone geometry and bone quality, and is expected to outlive any current conventional prosthesis.(21)

Sales in resurfacing implants are a fast-growing market worldwide, but the procedure has seen limited use in the United States.(22) In the United States, only one manufacturer has obtained FDA approval to market its hip resurfacing system. Smith & Nephew Orthopaedics received premarket approval from the FDA on May 9, 2006 for the Birmingham Hip Resurfacing system.(23,24) Femoral head resurfacing systems are cleared for marketing in the U.S. for use in hemi-resurfacing arthroplasty as discussed above.

Clinical data on the efficacy of total hip resurfacing are limited. A systematic review of studies on hip resurfacing was conducted by the U.K. National Health Service in 2002. They found that the data describing the procedure were too limited for firm conclusions to be reached.(19) Two studies, both published in 2004, have been cited as indicating good success rates but data were only available at 4 years of follow-up.(17) The average patient age in both studies was 48 years. Periprosthetic fracture of the femoral neck is the most common complication with hip resurfacing systems, but better patient selection and improved surgical technique have reduced the frequency of this complication.(21,22)