# Literature Search Strategies

## Electronic Database Searches

The following databases have been searched for relevant information:

Name | Date limits | Platform/provider
The Cochrane Central Register of Controlled Trials (CENTRAL) | Inception through 2006, Issue 2 | www.thecochranelibrary.com
The Cochrane Database of Methodology Reviews (Methodology Reviews) | Inception through 2006, Issue 2 | www.thecochranelibrary.com
The Cochrane Database of Systematic Reviews (Cochrane Reviews) | Inception through 2006, Issue 2 | www.thecochranelibrary.com
Database of Abstracts of Reviews of Effects (DARE) | Inception through 2006, Issue 2 | www.thecochranelibrary.com
ECRI Health Devices Alerts | 1977 through March 2006 | ECRI
ECRI International Health Technology Assessment (IHTA) | Inception through March 2006 | ECRI
ECRI Library Catalog | Inception through March 2006 | ECRI
ECRI TARGET (Technology Assessment Resource Guide for Emerging Technologies) | Inception through March 2006 | ECRI
Embase (Excerpta Medica) | 1974 through March 21, 2006 | OVID
Health Technology Assessment Database (HTA) | Inception through 2006, Issue 2 | www.thecochranelibrary.com
MEDLINE | 1966 through March 21, 2006 | OVID
PubMed (PreMEDLINE, Publisher) | 1966 through April 25, 2006 | www.pubmed.gov
U.K. National Health Service Economic Evaluation Database (NHS EED) | Inception through 2006, Issue 2 | www.thecochranelibrary.com
U.S. National Guideline Clearinghouse™ (NGC™) | Through March 2006 | www.ngc.gov

## Hand Searches of Journal and Nonjournal Literature

Journals and supplements maintained in ECRI's collections were routinely reviewed. Nonjournal publications and conference proceedings from professional organizations, private agencies, and government agencies were also screened. Other mechanisms used to retrieve additional relevant information included review of bibliographies/reference lists from peer-reviewed and gray literature. (Gray literature consists of reports, studies, articles, and monographs produced by federal and local government agencies, private organizations, educational facilities, consulting firms, and corporations. These documents do not appear in the peer-reviewed journal literature.)

## Search Strategies

The search strategies employed combinations of freetext keywords as well as controlled vocabulary terms including (but not limited to) the following concepts. The strategy below is presented in OVID syntax; the search was simultaneously conducted across Embase, Medline, and PsycINFO. A parallel strategy was used to search the databases comprising the Cochrane Library.

## Medical Subject Headings (MeSH), Emtree, PsycINFO and Keywords

### Conventions

OVID
- $ = truncation character (wildcard)
- exp = “explodes” controlled vocabulary term (e.g., expands search to all more specific related terms in the vocabulary's hierarchy)
- .de. = limit controlled vocabulary heading
- .fs. = floating subheading
- .hw. = limit to heading word
- .md. = type of methodology (PsycINFO)
- .mp. = combined search fields (default if no fields are specified)
- .pt. = publication Type
- .ti. = limit to title
- .tw. = limit to title and abstract fields

PubMed
- [mh] = MeSH heading
- [majr] = MeSH heading designated as major topic
- [pt] = Publication Type
- [sb] = Subset of PubMed database (PreMedline, Systematic, OldMedline)
- [sh] = MeSH subheading (qualifiers used in conjunction with MeSH headings)
- [tiab] = keyword in title or abstract
- [tw] = Text word

## Embase/MEDLINE

English language, human

Set Number | Concept | Search statement
1 | Hip | Hip.de. or hip joint.de. or hip$ or femoral or acetabul$ or acetabulum$
2 | Arthroplasty | exp arthroplasty/ or acetabuloplasty.de or arthroplast$ or replace$ or implant$ or prosthe$ or endoprosthe$ or hemiarthroplast$
3 | Combine sets | 1 and 2
4 | Hip replacement (see note below) | arthropasty, replacement, hip.de. or hip prosthesis.de. or hip arthroplasty.de. or hip prosthesis.de. or total hip prosthesis.de.
5 | Combine sets | 3 or 4
6 | Limit by publication type | 5 not ((letter or editorial or news or comment or case reports or note or conference paper).de. or (letter or editorial or news or comment or case reports).pt.)
7 | Guidelines | 6 and (st.fs. or guideline.pt. or consensus.pt. or practice parameter or position statement or position paper or policy statement or standard$.ti. or guideline$.ti. or white paper or clinical pathway or practice guidelines.de. or exp practice guideline/ or consensus development.de.)
8 | Systematic reviews & metaanalyses | 6 and ((systematic review or meta analysis).de. or ((evidence base$ or methodol$ or systematic or quantitative$ or studies).mp. and (review.de. or review.pt.)))
9 | Reviews | 6 and (review$.ti. or review.de. or review.pt.)
10 | Combine sets | 7 or 8 or 9
11 | Remove overlap | Remove duplicates from 10

We used controlled vocabulary terms and keywords to represent the concept of hip replacement surgery. The term “hip surgery” if used would include an excess number of citations which have no bearing on this report.

## MEDLINE (PubMed) – 1/1/66 through 7/24/06

English language

Set Number | Concept | Search statement
1 | Arthroplasty | Arthroplast* OR replace* OR implant* OR prosthe* OR endoprosthe* OR heimarthroplast*
2 | Hip | Hip OR femoral OR acetabul*
3 | Combine sets | #1 AND #2
4 | Limit by subset | #3 AND premedline[sb]

Additional concepts | Bipolar* OR tripolar* OR “cushion bearing” OR “surface treated” OR “surface modified” OR ceramic OR