# Inventory of Prosthetic Hips Currently Available

The appendix contains a listing of commercially available prosthetic hips, their features and characteristics, and their current regulatory (US FDA and CE Mark) status. These data, which were acquired through a survey of manufacturers conducted by ECRI,(147) are current as of April, 2005 unless otherwise noted. While this list is as complete as we are able to make it, the data in the charts derive from suppliers' specifications and have not been verified through independent testing by ECRI or any other agency. Because test methods vary, different products’ specifications are not always comparable. Moreover, products and specifications are subject to frequent changes. ECRI is not responsible for the quality or validity of the information presented or for any adverse consequences of acting on such information.