# Overview

The following overview summarizes our findings to the key questions.

Note that generally, the included studies evaluated populations with high likelihood for OSAHS, without co-morbidities that may affect sleep parameters (e.g. cardiac insufficiency), who were young (approximately 50 years old), predominantly male, and with high BMI. The technology assessment excluded people who had been operated for OSAHS. The aforementioned caveats should be taken in mind when assessing the applicability of the findings to the Medicare population (see below for a relevant discussion).

## Key Question A1

Is laboratory-based polysomnography considered a “gold standard” for the diagnosis of sleep apnea?

Facility-based PSG is the reference method to identify people with AHI suggestive of OSAHS.

This does not mean that facility-based PSG is an error-free “gold standard” for the diagnosis of OSAHS. The diagnosis of OSAHS typically requires additional information (symptoms and signs, differentiation of other conditions that affect sleep).

Furthermore, there is evidence that for people with a high probability for OSAHS, use of facility-based PSG does not result in better outcomes over an ambulatory approach in terms of diagnosis and CPAP titration.

## Key Question A2

Which are the appropriate methods for the comparison of diagnostic test performance for obstructive sleep apnea?

Ideally, one would like to evaluate hard outcomes in subjects who were managed based on information from different sleep monitors. Typically, hard outcomes include mortality, cardiovascular morbidity, incidence of accidents, and similar endpoints. A randomized controlled trial (RCT) would be the ideal study design.

The vast majority of the existing studies directly compares the measurements of AHI (or RDI, or related indices) obtained with the portable monitors or facility-based PSG. When two measurements are compared, one may:

1. Assess the agreement of the individual measurements directly. This answers the question of whether the two measurements (e.g., AHI from facility-based PSG and AHI or RDI from portable monitors) are potentially interchangeable.
  a. Difference versus average analyses (Bland-Altman plots) are a suitable method to address this question
2. Assess the ability of portable monitors to predict AHI measurements in facility-based PSG that are suggestive of OSAHS or not suggestive of OSAHS.
  a. Assuming that the reference standard of facility-based PSG has negligible error in the measurement of AHI, sensitivity, specificity and likelihood-ratio-based calculations are suitable.

The philosophy behind these questions is very different. This is also true for the assumptions underlying the statistical methods that are used in their analyses. It is very common for researchers to use wrong statistical methods (Pearson’s correlation coefficient and ordinary least squares regressions) in measurement comparison studies.

## Key Question A3

Classification of portable sleeping monitoring devices (Types I, II, III and IV).

The American Sleep Disorders Association (ASDA) classified the devices that have been used in sleep studies into four categories, based on the signals they record. For example, facility-based PSG is considered a type I device, and is the most comprehensive. There is a progressive loss of sleep parameter information from type I and II monitors to type IV monitors. Information on sleep staging is lost in Type III monitors. Some or all information on airflow /effort is lost in Type IV monitors (Type III devices have to have at two airflow channels one of which can be an effort channel).

The ASDA classification serves to characterize the sleep monitors for operational purposes. It does not imply that e.g., all Type IV monitors are equivalent.

There are some difficulties with the aforementioned classification scheme, which cannot explicitly classify all existing portable monitors. This is especially true for newer portable monitors that measure bioparameters proposed in later years (and are not listed in the ASDA classification scheme). For example, according to the ASDA scheme, Type IV monitors measure only one or two bioparameters. However, there are monitors that measure more that two bioparameters but they do not meet the criteria for Type III devices. These would remain “unclassified”. In this technology assessment, we broadened the definition of Type IV to include all monitors that do not meet the criteria for Type III devices (despite the fact that they record more than two bioparameters). However we report separately Type IV monitors that record only one or two bioparameters from those that record more than two.

## Key Question B1

Ability of facility-based polysomnography versus portable monitors to predict response to CPAP and changes in clinical outcomes after CPAP treatment.

Baseline AHI from facility-based PSG is only modestly associated with response to CPAP (as conveyed by the assessed outcomes) among people with high probability for severe OSAHS. Thus, differences in baseline AHI cannot be used to accurately predict CPAP use or response to CPAP in this population.

In addition, a randomized study suggested that the increased accuracy in AHI estimation with facility-based PSG versus a type IV monitor does not translate to more accurate prediction of response to CPAP with respect to a quality of life outcome. This finding is in line with the aforementioned caveats and pertains to patients who are at the severe end of the AHI spectrum

## Key Question B2

How does the performance of portable monitors compare with facility-based polysomnography for the diagnosis of OSAHS?

The AHI (or RDI) measurements from portable monitors and facility-based PSG are not interchangeable (especially in the higher end of the AHI spectrum):

- Difference versus average analyses suggest that substantial differences in the AHI may be encountered between type II monitors and facility-based PSG, especially when the studies are not performed simultaneously, but at different nights. Even larger differences compared with facility-based PSG cannot be excluded for type III monitors; and more so for type IV monitors. This was true both for manual and automated scoring.

Nevertheless, portable monitors may be able to predict AHI suggestive of OSAHS in facility-based PSG. This is compatible with the above analyses, when the monitors disagree in how large a large AHI value is, but agree that it is high enough to be “suggestive of OSAHS”:

- Based on limited data, type II monitors may identify people with AHI suggestive of OSAHS with high positive likelihood ratios and low negative likelihood ratios. Type III monitors may have the ability to predict AHI suggestive of OSAHS with high positive likelihood ratios and low negative likelihood ratios for various AHI cutoffs in laboratory-based PSG, especially when manual scoring is employed. Studies of type IV monitors that record at least three bioparameters showed high positive likelihood ratios and low negative likelihood ratios. Studies of type IV monitors that record one or two bioparameters also had high positive likelihood ratios and low negative likelihood ratios, at least for selected sensitivity and specificity pairs from ROC curve analyses.
- Overall, the ability of portable monitors to predict AHI with facility-based PSG appears to be worse in studies conducted in the home setting compared to studies in the specialized sleep laboratory. Between-night variability is a plausible explanation: in the sleep-lab setting measurements are simultaneous, whereas in other settings (home, hospital ward, outside the sleep lab) measurements are performed in different nights.

What does AHI suggestive of OSAHS mean?

The actual diagnosis of OSAHS is not set solely on the basis of high AHI values. Whether an AHI value “suggestive of OSAHS” reflects the true diagnosis of OSAHS or not is dependent on several factors:

1. The actual AHI cutoff that was used.
2. The presence of conditions that affect sleep quality and may not equally identified by facility-based PSG and some portable monitors:
  a. People with cardiac insufficiency or atrial flutter who have Cheynne-Stokes respiration, and people with respiratory disturbances such as chronic obstructive pulmonary disease, obesity hypoventilation syndrome, or people with other sleep disorders such as narcolepsy.
  b. Periodic Limb Movements in Sleep (PLMS), which are observed in the majority of patients with the Restless Leg Syndrome (RLS).
3. The prior probability of OSAHS. People with high prior probability of OSAHS would be:
  a. Referrals from physicians familiar with OSAHS
  b. People with symptoms or suggestive clinical profile

Applicability to the Medicare population:

Three caveats may be made:

First, the prior probability of OSAHS among Medicare beneficiaries may be lower than the prior probability of OSAHS among subjects analyzed in the included studies:

1. The average age of the participants in the analyzed studies was recorded. The median value was 50 to 52 years. Moreover, the majority of the subjects were males and they had BMI above 25 kg/m^2^. Finally, in most studies subjects were referred for PSG by sleep or respiratory physicians. On the other hand, Medicare beneficiaries are older (≥65 years), are not predominantly male, and may often have comorbidities that affect sleep quality.
2. There is evidence that, in the elderly, obesity and daytime somnolence may not be as strongly associated with OSAHS as in middle aged people.15 In other words, a high AHI or RDI value would not be as strongly associated with an actual diagnosis of OSAHS.

Second, facility-based PSG can differentiate OSAHS from other conditions that cause sleep disturbances (such as PLMS/RLS, or conditions associated with mixed or central apneas or hypopneas). The following caveats may be made:

1. Conditions that are associated with sleep disturbances with a central component (such as e.g., cardiac insufficiency) are prevalent among Medicare beneficiaries. This may be true for respiratory conditions (chronic obstructive pulmonary disease, obesity hypoventilation syndrome and other hypoventilatory syndromes) as well as other sleep disorders like narcolepsy. This caveat probably pertains to type III and type IV monitors.
2. Oximeters (and some monitors that do not assess airflow or effort) may not be able to differentiate PLMS/RLS from OSAHS. The prevalence of RLS is increased among older adults (up to 8% in people older than 60 years, compared to approximately 5% in people who are in their forties).137 Moreover, PLMS/RLS is more common in women,137 who were the minority in the studied populations. This caveat pertains to some type IV monitors that assess one or two bioparameters only.

Finally, in almost all eligible studies the investigators were associated with sleep clinics and/or sleep laboratories. Study investigators are probably very familiar with the diagnosis and treatment of sleep disorders (including ones other than OSAHS) even when this is not clearly stated in the primary papers). One cannot necessarily extrapolate the findings in these studies to circumstances where health care providers with less training and experience might use the devices.

For studies in the home setting, do technologist support and patient education affect the comparison of portable and with facility-based polysomnography for the diagnosis of OSAHS?

For studies in the home setting, there is no direct data on whether and to what extent technologist support and patient education affect the comparison of portable monitors with facility-based polysomnography.

## Key Question B3

How do automated and manual scoring compare in the diagnosis of obstructive sleep apnea?

Overall, manual scoring or manual editing of automated scoring seems to have better agreement with facility-based PSG compared to manual scoring in the studies that assessed both scoring methods. We note that the automated scoring algorithms from different monitors are different, and their ability to recognize respiratory events may vary with the specific software version or settings.

What errors related to automated and manual scoring are reported?

We did not identify detailed data on the specific types of errors that are related to automated or manual scoring rather than other parameters. No robust conclusion can be given for this question.

## Key Question B4

For studies of portable monitoring in the home setting, what errors related to unattended use are reported?

No studies of type II monitors associated directly any specific errors with unattended use. However, signal loss was more often observed for home studies. Two studies of type III monitors in the home setting were unattended but used a built in alert to notify the user for errors, or a modem connection to send recorded data to a technologist. Indirect evidence suggests that errors were possibly prevented using the aforementioned mechanisms (instead of physical presence).

## Key Question B5

Do the reported complications, harms, and adverse events differ for portable multichannel sleep testing and facility-based polysomnography?

The rate and severity of adverse events in sleep studies are low. In a large study, complications were identified in less than 0.5% of the recordings during facility-based PSG. Complications were not reported in the remaining studies, and mostly minor harms were reported to the FDA adverse events database. This conclusion applies to both facility-based PSG and to portable monitors. An advantage of facility-based PSG was the ability of specialized personnel to intervene in case of events necessitating immediate attention (i.e., mostly arrhythmias associated with sleep disordered breathing).

## Key Question B6

Do rates or types of data loss and data corruption differ for portable multichannel sleep testing and facility-based polysomnography?

Rates of unsatisfactory studies and data corruption are higher for portable monitors in the home setting, compared to facility-based PSG, or portable monitors in the sleep laboratory setting. This is probably attributed to user errors during device operation or probe hook-up for home studies, and probably also to the absence of an attending technologist.