# Methods

This technology assessment has two aims, as described in the Statement of Work. Aim A is a discussion of important relevant topics and is based on narrative reviews. Aim B is based on a systematic review of the literature.

## Terminology and definitions

For this report, we will use the following definitions and terms throughout the technology assessment.

### Disease

Obstructive Sleep Apnea Hypopnea Syndrome and Obstructive Sleep Apnea are terms that refer to the same entity. The latter name is used in the International Classification of Diseases (ICD) scheme and in the standard classification in the International Classification of Sleep Disorders (ICSD) – Diagnostic and Coding Manual. However, we retain the more descriptive OSAHS throughout this technology assessment.

### Respiratory events

OSAHS is characterized by the presence of respiratory events during sleep. The following respiratory events are of interest (all events are defined for a minimum duration of 10 seconds):

- Apnea is the cessation of airflow. Some studies have defined apnea as a very large reduction in airflow (more than approximately 80% of baseline), but not necessarily complete cessation; this is because of the inability of airflow probes to differentiate complete cessation from very low flow.
- Hypopnea is a reduction in airflow compared to “baseline” airflow. The definition of “baseline” airflow may influence the number of hypopneas that are scored, especially in patients with lung disease and fluctuating ventilation. The definition of “baseline” airflow is not reported in most papers. Definitions for hypopnea vary across studies. Hypopneas have been defined as reductions in airflow alone or reductions in airflow associated with other events (such as arousals or oxygen [O_2_] desaturations). The magnitude of airflow reduction may be quantitatively or qualitatively defined. Usually employed quantitative definitions identify hypopneas with reductions in the amplitude of the airflow signal of a given magnitude (e.g., at least 50%). Studies employing qualitative definitions identify hypopneas with “discernible airflow reductions” (again due to the inability of airflow probes to reliably quantify low flow).
- Other respiratory events. Depending on the signals gathered during the sleep study, definitions of the respiratory events may differ. For example, if only oximetry were used, the degree and frequency of desaturations would be assessed as proxies for apneic and hypopneic respiratory events. Additionally, recent evidence suggests that arousals from sleep due to respiratory efforts against a blocked or partially blocked upper airway contribute significantly to cardiovascular disease in these patients. An additional respiratory event that has been described is the Respiratory Effort Related Arousal (RERA). This occurs when there is a discernible reduction in the nasal pressure cannula signal associated with an arousal from sleep. RERAs are validated by esophageal pressure monitoring.1,23,24

### Sleep time

- Total recording time or total time in bed is the time period a person spent in bed or the total duration of the sleep study. This time interval is otherwise referred to as the time that lapsed between lights off and lights on. It is measured in facility-based PSG to determine overall sleep efficiency (total sleep time divided by total recording time), and it is measured in portable monitor studies as well. In many portable monitor studies it is used as a proxy for the actual total sleep time.
- Total sleep time pertains to the total time a person spent sleeping, and is by definition shorter than the total recording time. To estimate the total sleep time, sleep staging must be performed. The most often employed criteria for sleep staging in sleep studies are the criteria of Rechtchaffen and Kales.25

Figure 1 illustrates the distinction between total recording time and total sleep time.

Figure 1 Total sleep time and total recording time

The total recording time in a sleep study consists of the total time spent asleep (horizontal thin line segments) and the time the patient is aroused (horizontal bold line segments). The total sleep time excludes arousal periods and is by definition shorter or at most (i.e., in the absence of arousals) as long as the total recording time. (N.B., This figure is only a schematic and the lengths of the arousal or sleep periods or their numbers are not drawn to scale).

Figure 1. Total sleep time and total recording time.

### Apnea-Hypopnea Index (AHI) and Respiratory Disturbance Index (RDI)

The frequency of respiratory events during sleep can be used to quantify the severity of OSAHS.

frequency of respiratory events = (N_respiratory events_)/(Total sleep time)

The following two indices are used to quantify the severity of OSAHS in most studies. Other indices have also been used.

- Apnea-Hypopnea Index (AHI). The number of apneas and hypopneas per hour of sleep. It is a fraction, where the numerator is the number of apneas and hypopneas, and the denominator is total sleep time.
- Respiratory Disturbance Index (RDI). We caution that studies of portable monitors do not define RDI in the same way it is defined in everyday clinical practice in the sleep laboratory (i.e., the quotient of the total number of RERAs, apneas and hypopneas divided by total sleep time). In studies of portable monitors RDI is a quantity that approximates AHI, whenever the numerator (apneas or hypopneas) or the denominator (total sleep time) or both are not measured directly. In most cases the denominator is the total recording time instead of the total sleep time. Proxies for the numerator vary depending on the recorded signals and their assessment. Therefore exact definition of RDI may vary across different studies of portable monitors. Throughout the technology assessment, we refer to RDI in the way it is defined in portable monitor studies.
- Other indices are not used as extensively or may be signal-specific. The apnea index (AI) is defined similarly to the AHI, but ignoring hypopneas in the numerator (e.g., see Fleury 1996^26^). In some studies of oximetry-only recordings, the oxygen desaturation index (ODI) is used. This is typically the number of times the O_2_ saturation drops by a certain percentage (4% usually) per hour of recording time. Other oximetry studies measure the “delta index” (it assesses serial changes in O_2_ saturation, e.g., Pepin 1991^27^). Snoring intensity (e.g., Esnaola 1996 and Koziej 1994,28,29) or other indices have also been used.

### Cardiorespiratory and neurophysiologic signals

During sleep studies, several types of data (signals) are recorded in the pertinent monitor channels and are then evaluated. These signals are physiologic measurements. Table 1 provides a simplified description and explanation of the use of different signals that are usually recorded in sleep studies. This list is not exhaustive.

Table 1 Often used signals in sleep studies

Signal | Description | Probes^*^
Signals used to define respiratory events (“numerator”)
Airflow | To define apneas or hypopneas | Thermistor (nasal, oronasal); nasal cannula; tracheal microphone
Effort | Respiratory effort, movement of the diaphragm or the rib cage | Thoracoabdominal piezoelectric belts; inductance plethysmography; intercostal-muscle EMG; diaphragm EMG
SaO_2_ | O_2_ saturation of arterial blood | Oximetry (ear lobe; digit)
Signals used to define sleep time (“denominator”)
EOG | To identify REM sleep | Electrodes (may be bilateral)
EEG | Cerebral activity | Electrodes (e.g., 4 electrodes)
Chin (submental) EMG | Increased tone is associated with arousal | Electrodes (may be bilateral)
Anterior tibialis EMG | Increased tone is associated with arousal | Electrodes (may be bilateral)
ECG | To measure heart rate or to quantify its variability (an estimate of sympathetic activity) | Usually a single electrode to estimate the RR interval
Body position sensor | Describes sleep position | e.g., Mercury switch
Video monitoring | Describes sleep position, differentiate periods of mouth breathing from apneas, etc. | Infrared-sensitive camera
Actigraphy sensor | Describes acceleration and | e.g., Wrist actigraphy

* the list is not exhaustive

ECG: electrocardiogram; EEG: Electroencephalogram; EMG: electromyography; EOG: Electro-oculogram; REM: Rapid eye movement

Note that the list of channels is not exhaustive. Refer to text for a description of channels used by different types of monitors.

### Types of monitors used in sleep studies

The American Sleep Disorders Association classified the different monitors that have been used in sleep studies into four categories, depending on which channels they record and evaluate.21 Details on the classification of sleep monitors and a discussion on how newer devices may fit in this classification scheme are provided in Section A3.

Here, we used the operational rules described in Table 2 to classify sleep monitors. Very similar rules have been applied in previous systematic reviews.13 Briefly:

- Type I is facility-based PSG.
- Type II monitors record the same information as type I (perhaps with fewer channels). Type II monitors record signals that allow the reliable identification of (micro)arousals from sleep (e.g. EOG, chin EMG, EEG – see Table 1 for abbreviations) and at least two respiratory channels (two airflow channels or one airflow and one effort channel).
- Type III monitors do not record the channels that differentiate between sleep and wake, but have at least two respiratory channels (two airflow channels or one airflow and one effort channel).
- Type IV are all other monitors that fail to fulfill criteria for type III monitors. Therefore type IV channels may include monitors that record more than 2 bioparameters.

We classified each monitor according to the channels that were actually used in the pertinent study. For example, if not all channels of a nominally type III monitor were used or analyzed, we classified the monitor as “type IV” for the particular study. This “downlabeling” occurred rarely; it is always clearly noted in the corresponding tables and text.

Table 2 Delineation of operational rules used to classify monitors in sleep studies

Type or Level | Portability | Indicative N_channels_ | Indicative signals | ≥2 airflow /effort channels | Identifies sleep /wake | AHI
I | Facility-based | ~14–16 | EEG, EOG, EMG, ECG/HR, airflow, effort, SaO_2_ | Yes | Yes | Yes
II | Portable | ≥7 | (may have EEG), HR^*^, EOG, chin EMG, ECG/HR, airflow, effort, SaO_2_ | Yes | Yes | Yes
III | Portable | ≥4 | Airflow and/or effort, ECG/HR, SaO_2_ | Yes | No | No
IV | Portable | ~1–3^**^ | [All monitors not qualifying for type III] | No | No^***^ | No

AHI: Apnea-Hypopnea index; ECG: electrocardiogram; EEG: Electroencephalogram; EMG: electromyography; EOG: Electro-oculogram; HR: heart rate; SaO_2_: arterial O_2_ saturation;

* Heart rate is allowed instead of EEG in type II monitors. Essentially, many type II monitors gather the same signals as type I monitors.

** May have more than three channels, provided that criteria for type III are not met

*** May include monitors that measure signals that are in principle able to identify arousals from sleep.

### Other definitions and terms

#### Scoring of sleep studies

The interpretation of the recording from a sleep study may be:

- Manual, i.e., performed by a technologist/sleep expert or a sleep physician using predefined criteria. The interpreter may use proper software that facilitates the display of the signals on a screen, but does not score the recordings.
- Automated, i.e., the signal is analyzed during its recording or later, and the interpretation of the recording is performed by specialized software. The software identifies the respiratory events using specialized algorithms (and some pieces of software may also crudely evaluate the actual sleep time; e.g., see Pillar 2003^30^), whichtypically vary by the specific make of monitor.
- Combined automated and manual, i.e., automated analysis with human supervision. This typically pertains to manual corrections on the results of the automated analysis. An additional scenario is when a technologist selects parts of the recordings for software analysis based on signal quality or absence of artifacts.

#### Setting

Studies with type I monitors (facility-based PSG) are conducted in specialized sleep centers/laboratories. Sleep studies with portable monitors may be:

- Home-based, when the study is conducted at home.
- Hospital-based when the study is conducted in a hospital ward that is not part of a specialized sleep clinic or a sleep laboratory
- Sleep clinic-based, facility-based or sleep laboratory-based, when the study is conducted in a specialized facility.

#### Attendance

Sleep studies performed in the hospital or in the sleep lab (with any type of monitor) may be:

- Attended, if a technologist supervises the recording during sleep time, and has the ability to intervene if needed. This means that the technologist would correct any mistakes leading to bad quality of signals or loss of signals (e.g., probe displacement, or probe failure).
- Unattended, if there is no supervision by a technologist during sleep time. These sleep studies may have been home-based or laboratory-based. We classified all sleep studies with portable monitors that were home-based as unattended, including the ones with a continuous feedback to a sleep technologist in the hospital over a modem connection.31 The same was true for monitors that have incorporated self-check algorithms and alert (wake) the evaluated subject if a probe is not properly connected or dislodged.32

## Search Strategy

We conducted comprehensive searches in MEDLINE from its inception through the 28^th^ of February 2007 to identify English language publications that described prospective studies comparing portable monitors with facility-based PSG, or describing adverse events or complications of sleep studies. Because different questions were added at different time points, three electronic searches were performed. Searches were incremental (i.e., the latest search included all the citations of the previous searches). Relevant systematic reviews and meta-analyses, consensus statements and recommendations were also identified. Various search terms were used, including terms that described sleep studies with different monitors, OSAHS, and continuous positive airway pressure (CPAP) treatment for OSAHS. The complete search strategy is reported in detail in Appendix A. Reference lists from relevant systematic or non-systematic reviews, the reviewed studies, and publications on practice recommendations were also examined for potentially useful additional citations.

Because rare adverse events or complications would probably not be described at all in the eligible studies (see below for eligibility criteria), the website of the Center for Devices and Radiological Health of the US Food and Drug Administration (FDA) was searched. Specifically, the database of adverse events secondary to medical device use was queried for all available years (1992–2006) using the general term “sleep stud*” (last search December 12, 2006). The database is publicly accessible at http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfMAUDE/search.cfm.

## Inclusion and exclusion criteria

After consultation with our technical expert, AHRQ and CMS, we considered all research studies published in English that met the criteria described in the following sections.

### Participants

Disease-free participants, people suspected of OSAHS, or patients with any diagnosis of OSAHS were eligible, provided that they were adults, medically stable and had not been subjected to OSAHS-related surgery. Studies were eligible irrespective of the potential presence of comorbidities, such as chronic obstructive pulmonary disease and congestive heart failure, racial, or gender distributions. For studies comparing the diagnostic ability of sleep monitors, 11 or more participants had to be analyzed after any exclusions or dropouts. For studies assessing adverse events only, 101 or more subjects had to be included. Studies evaluating the ability of facility-based PSG to predict response to CPAP treatment had to have at least 2 weeks duration of CPAP treatment. These cutoffs are arbitrary, and are set to distinguish studies that are small (and perhaps less likely to be informative). For example the sensitivities and specificities obtained from a diagnostic study on 10 people would be extremely uncertain (would have very wide confidence intervals). Similarly, for adverse events, it is likely that less common adverse events and harms will be observed in studies much larger than 100 participants.

### Interventions and assessments

Any sleep studies that were performed with facility-based PSG or portable monitors:

1. For the assessment of the diagnostic ability of portable monitors, eligible studies comparing measurements with portable monitors and facility-based PSG in the same patients, either simultaneously, or within three months of the two measurements (provided that no active treatment was offered between the measurements). For the assessment of type II monitors versus facility-based PSG, we also accepted studies that compared unattended type II monitors at home with attended type II monitors in the hospital. This exception was allowed because of the relative paucity of data on type II monitors, and because type II monitors essentially record all the signals that non-portable, facility-based PSG records.
2. Only one monitoring device (either portable monitor or facility-based PSG) was sufficient for:
  2.1. The assessment of the relationship between baseline severity of OSAHS (as conveyed by AHI, RDI or other indices obtained from facility-based PSG or portable monitors) and the response to CPAP treatment.
  2.2. The comparison of the diagnostic ability of manual versus automated scoring of recordings and errors, adverse events, or complications related to different scoring methods
  2.3. Errors, adverse events, or complications related to unattended sleep studies, or sleep studies with different monitors.
  2.4. Rates of data loss from sleep studies with different monitors.

All types of devices were eligible. However, especially for type IV devices, we excluded the few studies that did not measure directly at least one respiratory signal or the O_2_ saturation. Thus, studies using only static charge-sensitive mattresses, only Holter recordings for heart rate, or studies that used only analysis of snoring sounds were excluded. Similarly, we excluded studies that that used pulse oximetry but analyzed only the variability of the heart rate (i.e., used oximetry in lieu of ECG to detect pulse rate) and did not evaluate O_2_ saturation patterns. In general, monitors that did not record a respiratory signal or SaO_2_ during sleep rely on “indirect” assessment of respiratory disturbances in people suspected for OSAHS, and most often were described in older studies. The frequency of respiratory disturbances is a key issue in the diagnosis of OSAHS, and is assessed by the vast majority of modern monitors.

### Eligible outcomes - eligible methods of analyses

#### Ability of AHI or RDI to predict response to CPAP

Any outcome or any measure of association was eligible.

#### Assessment of concordance between measurements

The reader is referred to Section A2 for a discussion of appropriate methods to assess the concordance of paired measurements. We a priori decided that eligible methods for the assessment of concordance of the measurements were:

1. Difference versus average analyses using either untransformed measurements or using the logarithmic transformation (the only transformation that has a natural meaning in the context of measurement method comparison). This type of analysis is otherwise referred to as Bland-Altman plots, after the researchers that advocated their widespread use.33,34
2. Lin’s concordance correlation coefficient35,36 or intraclass correlation coefficients.
3. Weighted or unweighted κ for agreement.

Moreover, studies reporting sensitivity and specificity pairs, or receiver operating characteristic curve analyses (assuming that measurements with facility-based PSG have negligible error for any practical purposes) were also eligible.

#### Evaluation of errors, adverse events or complications

Any mention of the above was eligible.

#### Outcomes or metrics that were not summarized

We did not summarize evidence on the repeatability of measurements with the same device, or assessments of concordance using the Pearson correlation coefficient or ordinary least-square regressions. See Section A2 for the rationale that supports this decision. We also did not review evaluations that utilized respiratory events rather than participants as a unit of analysis.

### Design

In principle, comparative trials (randomized and non-randomized) that assessed hard clinical outcomes (mortality, cardiovascular morbidity and similar outcomes) across patients managed using laboratory-based PSG measurements and patients managed using portable monitoring would be eligible, but none was found.

Only prospective studies were assessed. For the questions on the concordance of the measurements with different monitors, we excluded studies with overt verification bias (i.e., studies where only those with high RDI in the portable monitor were assessed with facility-based PSG). We note that this does not mean that all included studies are immune to verification bias, as it is very possible that such selections might have been made but not reported in the published paper.

## Data abstraction

All studies were extracted in preconstructed forms. The forms were piloted in a set of 6 studies (two for each type of portable monitor) and corrections were made. Because more questions were added to the technology assessment during the data extraction, the forms were amended, and the already reviewed or excluded papers were re-evaluated for potential eligibility for the added questions. A version of the data extraction form was used for studies that were being evaluated for description of adverse events, complications, or harms. Appendix B depicts the final versions of the data abstraction forms. Briefly, we recorded information on the citation, patient sampling, pretest probability of OSAHS, characteristics and details of the sleep monitors used and the setting of their use, agreement between measurements or other results as applicable, information on signal loss, and methodological quality items.

Whenever data were reported in good quality graphs, they were electronically digitized using specialized software (Engauge Digitizer, ver 2.14, Mark Mitchell). The digitized data points were then re-analyzed by the Tufts-NEMC EPC to verify and complement information on the studies’ results. This was usually necessary for studies that did not assess the concordance of the measurements using difference versus average plots, but only provided a scatter plot of the measurements with the two compared methods. Because digitizing and re-analyzing is a very time-consuming exercise, 10 figures were not digitized. However, the non-digitized papers already provided in tables and in the text almost all pieces of information needed for the purposes of the technology assessment.

All papers were extracted in duplicate. Duplicate extraction was completely blinded for approximately a third of the papers. A critical corroboration of the abstraction form against the published paper was undertaken in the remaining two thirds of the papers. All included and excluded papers were reviewed in detail by the first author, who was also the arbitrator for potential discordant items.

## Analyses

### Assessing whether baseline AHI or RDI predicts response to CPAP

The association between baseline AHI or RDI and the response to CPAP or adherence to CPAP use was assessed quite differently in the identified studies, precluding any quantitative synthesis. Any measure of response to CPAP was acceptable, and these included quality of life outcomes, objective, or subjective symptom scores, changes in blood pressure, weight loss or other indices. We accepted only objective methods of quantifying adherence, because self-reporting has been shown to be very inaccurate. Thus, sufficient CPAP use (as defined in each study) had to be documented by reading data from built in covert or overt modules that measured the length of actual use. CPAP use had to be least 2 weeks long in all eligible studies. We did not exclude studies that also used other interventions (e.g., weight loss interventions).

Given the nature of the available data and the confounding by other interventions, it is clear that any findings from these assessments should be considered hypotheses forming and should therefore be interpreted with caution.

### Comparison of measurements with different methods

For the comparison of the measurements with portable monitors versus facility-based PSG, we grouped studies by type of portable monitor (II, III, IV), setting (home, hospital ward-non-specialized units, specialized sleep units), and scoring method (manual, combined manual and automated, or automated). Especially for type IV monitors, we also distinguish between type IV monitor that recorded only one or two bioparameters from monitors that recorded more than two bioparameters (see Section A3 for more discussion).

Findings of studies falling in the same groups were evaluated comparatively as described below.

#### Assessing the agreement between measurements

The concordance of two measurements is commonly assessed by difference versus average plots (Bland-Altman plots– see Section A2 for a description).33,34 For each study with available information (either reported in the paper or after figure digitizing), we visually depict the average difference between the two measurements and the spread of the 95% limits of agreement (i.e., the boundaries that include the 95% of the differences between the two measurements) (see Section A2). Note that these visual descriptions do not inform on potential changes in the difference between the two measurements at different levels of the measured quantity. Such dependencies were assessed with the Bradley and Blackwood F test37 for digitized data, or as described in the papers for non-digitized graphs.

Analyses with difference versus average plots assume that none of the two methods is better than the other; they merely assess their concordance. For type IV monitors versus facility-based PSG this assumption may not be strictly true. Theoretically, Type IV monitors utilize only a fraction of the information available in facility-based PSG. This is true for type III monitors also, but for type IV monitors this is even more pronounced.

#### Assessing the ability of portable monitors to predict AHI values suggestive of OSAHS with facility-based PSG

For these analyses, we assumed that facility-based PSG AHI estimates had negligible error for any practical purposes. A detailed description of quantities that were used in the assessment of the diagnostic ability of portable monitors (namely sensitivity, specificity and likelihood ratios) is provided in section A2, along with additional methodological and statistical considerations.

Briefly, the sensitivity and specificity of the portable monitors were derived and visually depicted in (square sensitivity/1-specificity) plots. Studies that yielded high positive likelihood ratio and/or low negative likelihood ratio were identified. For operational cutoffs for a high positive likelihood ratio and a low negative likelihood ratio we used the values 10 and 0.1, respectively (see Section A2 for a more detailed description).38

Finally, AHI cutoffs suggestive of OSAHS were defined differently across studies, or even in the same study. Main emphasis was given to the cutoff of 15 events/hour of sleep. This AHI cutoff is part of the Medicare reimbursement criteria that describe eligibility for CPAP treatment, and is usually considered as suggestive of OSAHS by many experts.39 (Also, see results under Aim B, the majority of the studies used 15 events/hour as a cutoff). However, for completeness, findings from studies using AHI cutoffs of 10 and 20 events/hour of sleep were also presented.

Note that summary estimates of sensitivity and specificity from separate meta-analyses and summary ROC analyses were not presented. It is arguable whether it is meaningful to provide any summary estimates even for monitors that belong to the same type (and have even been studies in the same setting) because quite different definitions for RDI have been used. The qualitative description of the studies’ findings was deemed sufficiently informative.

### Comparison of rates of data loss, errors, harms, adverse events and complications

Errors resulting in data loss during sleep studies were differently defined across studies. For operational purposes, we adopted each study’s definition of an unsatisfactory sleep recording. Because of the variability and the inconsistency of reporting, only qualitative assessments were performed.

There is no clear definition of harms, complications, or adverse events. Thus, any information that was deemed relevant was recorded. Differences in definitions across studies are unavoidable. Therefore, only qualitative descriptions of these rates were performed.

## Assessing individual studies

### Applicability and quality of studies

The applicability of individual studies to the Medicare population of interest was assessed based on baseline severity of OSAHS (as conveyed by the mean AHI with facility-based PSG), the gender distribution of the participants, their mean age and body mass index, the potential presence of comorbidities, and the selection criteria of the individual studies (sampling population).

We did not assess the quality of studies that reported errors, adverse events, harms or complications. Any information on harms is important, irrespectively of study design and overall methodological quality. According to the inclusion criteria, all studies were prospective and without overt verification bias. Thus, we further assessed the methodological quality of the studies comparing measurements with different methods based on several quality items: blinding of assessors to results of the other test, blinding to clinical information, enrollment of consecutive patients, random order of measurements or simultaneous measurements with the compared methods, proportion of data loss and clear description of the evaluated population. Quality was evaluated using a three-point scale (A, B, C or good, moderate, poor).

Grade A (good methodological quality) studies fulfill most commonly held concepts of high quality, including the following: blinding of assessors to results of the other test, blinding to clinical information, enrollment of consecutive patients, random order of measurements or simultaneous measurements with the compared methods, clear description of the evaluated population, setting, and measurement methods; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; not excessive data loss (<20%); and no obvious bias.

Grade B (moderate methodological quality) studies may be susceptible to some bias, but not sufficient to invalidate the results. Such studies do not meet the criteria described in category A. They have some deficiencies but none likely to cause major bias. Study may be missing information making assessment of the limitations and potential problems difficult.

Grade C (poor methodological quality) studies are subject to significant bias that may invalidate the results. Such studies may have serious errors in design, analysis or reporting. These studies may have large amounts of missing information or discrepancies in reporting.