# Introduction

## Obstructive Sleep Apneas-Hypopnea Syndrome (OSAHS)

Obstructive Sleep Apnea (OSA) is a relatively common disorder that could affect all ages. The condition is characterized by periods of disturbed airflow patterns during sleep time, namely reduced airflow (hypopnea) or airflow cessation (apnea). It is postulated that both types of airflow disturbance have similar pathophysiology and bear the same clinical significance.1 Obstructive sleep apnea-hypopnea syndrome (OSAHS) is the most common type of the condition (apneas and hypopneas of central and mixed central and obstructive etiology comprise the other forms).1 OSAHS has been associated with a variety of adverse clinical outcomes such as mortality secondary to stroke and cardiovascular events,2,3 decreased quality of life,4 cardiovascular disease and stroke,2,5 hypertension,6–8 diabetes and other metabolic abnormalities,9,10 as well as increased likelihood for driving11,12 and other types of accidents.

## Assessing the presence and quantifying the severity of OSAHS

The severity of OSAHS is typically quantified by the number of apneas and hypopneas per hour of sleep, a quantity that has been termed Apnea-Hypopnea Index (AHI). Different populations have different AHI values. Specific cutoffs are typically used to establish the diagnosis of OSAHS.1,13 For example, as of this writing, the Medicare criteria for reimbursement of continuous positive airway pressure (CPAP) therapy are AHI ≥15 events/hour, or AHI ≥5 events/hour associated with symptoms (e.g., daytime somnolence and fatigue). However, a variety of AHI thresholds ranging between 5 and 40 have been used as suggestive of OSAHS in different studies.

Approximately two to four percent of middle-aged women and men, respectively, have been estimated to have an AHI≥15 events/hour and excessive daytime somnolence in the population-based Wisconsin Sleep Cohort Study.4 Using an AHI cutoff of ≥5 events/hour without the symptoms of excessive daytime sleepiness puts the prevalence at 9% for women and 24% for men. The symptom of excessive daytime sleepiness is quite variable and not always present in patients with OSAHS. Thus, most people suffering from OSAHS remain undiagnosed and untreated.4 More recent studies also suggest a high prevalence (i.e., prevalence of AHI ≥ 5 in adults age 30–69 of 17%), perhaps due to increasing obesity rates in later years.14

The prevalence of the condition among Medicare beneficiaries (people aged 65 years or older) is believed to be higher than the aforementioned estimates among middle-aged people. In the population-based Sleep Heart Health Study the prevalence of AHI≥15 events/hour was 1.7-fold higher in people older than 60 years compared to people between 40 and 60 years of age.15 Similar observations were made in cohort studies that used population-based samples and a wide range of ages.16–19 However, scant data suggest that the prevalence of OSAHS does not continue to rise with age in older adults, but reaches a plateau after the age of 60–65 years.15,20 This implies either a relative increase in mortality from OSAHS, or a remission of OSAHS with advancing age.

Apart from the use of AHI, other methods to quantify severity have also been used in various studies. These mainly pertain to the evaluation of O_2_ desaturations during sleep, the evaluation of other respiratory events such as the Respiratory Effort Related Arousals, or the degree of daytime fatigue and somnolence.

The standard measurement of AHI (and the diagnosis of OSAHS by extension) requires a comprehensive, technologist-attended sleep study with multichannel polysomnography (PSG), which is performed in specialized sleep laboratories.1,13 Laboratory-based PSG records a variety of neurophysiologic and cardiorespiratory signals and is interpreted by trained technologists and sleep physicians after the sleep study has been completed. Because of the high demand, the associated costs and the need for timely diagnosis, portable devices have been developed to substitute for laboratory-based PSG.13 There are different types (classes) of portable monitors.21 Each gathers different neurophysiologic and respiratory information and may synthesize the accumulated data differently.21 Depending on the data they record, portable monitors are classified in different categories (which are discussed in more detail later in this technology assessment).21 Portable monitors can be used not only in the home setting, but in the hospital and clinics other than specialized sleep units.

## Statement of Work

The Center for Medicare and Medicaid Services (CMS) has requested a technology assessment through the Agency for Healthcare Research and Quality (AHRQ) on the role of home monitoring for the diagnosis of OSAHS. On September 28, 2004, the evidence on home monitoring devices in the diagnosis of sleep apnea was discussed at a Medicare Coverage Advisory Committee meeting. The RTI EPC presented a technology assessment on this topic,22 which was an update of a prior technology assessment done for the American Academy of Sleep Medicine, the American Thoracic Society, and the American College of Chest Physicians.13 CMS has requested an update of the evidence presented in the RTI EPC technology assessment on home sleep monitoring with an expanded scope, including the assessment of the ability of PSG indices to predict a response to CPAP treatment. More specifically, the following aims were defined by CMS and AHRQ after discussions with the Tufts-NEMC EPC:

### Specific aims

A. Provide a discussion on the following topics:
  A1. Discuss whether facility-based polysomnography is considered a “gold standard” for the diagnosis of sleep apnea.
  A2. Discuss the appropriate methods for the comparison of diagnostic test performance for obstructive sleep apnea.
  A3. Discuss the classification of sleep monitoring devices (Types I, II, III and IV).
    A3a. Discuss the relationship between the measurement of parameters of sleep and cardiorespiratory function (i.e., sleep staging, body position, limb movements, respiratory effort, airflow, oxygen saturation, electrocardiogram [ECG]), and the accuracy of diagnosis of sleep apnea.
B. Summarize the scientific evidence on portable monitoring for the diagnosis of obstructive sleep apnea. In particular, summarize evidence on the following questions:
  B1. Among patients diagnosed with obstructive sleep apnea (OSA) and considered for treatment with CPAP (of any form), how does baseline diagnosis by portable polysomnography compare with facility-based polysomnography in predicting the response to CPAP and clinical outcomes?
  B2. How does the performance of portable multi-channel sleep testing compare with facility-based polysomnography (full or split night) for the diagnosis of obstructive sleep apnea?
  B2a. For studies of portable monitoring in the home setting, how do factors such as technologist support and patient education affect the comparison of portable multi-channel sleep testing with facility-based polysomnography for the diagnosis of obstructive sleep apnea?
  B3a. How do automated and manual scoring compare in the diagnosis of obstructive sleep apnea?
  B3b. What errors related to automated and manual scoring are reported?
  B4. For studies of portable monitoring in the home setting, what errors related to unattended use are reported?
  B5. Do the reported complications, harms, and adverse events differ for portable multichannel sleep testing and facility-based polysomnography?
  B6. Do rates or types of data loss and data corruption differ for portable multichannel sleep testing and facility-based polysomnography?

## Follow-on project

Finally, as a follow-on project, Tufts-New England Medical Center EPC will create a decision model to assess management strategies for patients with high clinical suspicion for OSAHS.