# Information on overall methodological quality grading

The following appendix tables are provided as a quick description of methodological quality items that were used to characterize the overall methodological quality of the studies. Note that overall study quality may be penalized when improper statistical analyses are used or when data from text, figures and tables do not corroborate. We remind that:

Grade A (good methodological quality) studies fulfill most commonly held concepts of high quality, including the following: blinding of assessors to results of the other test, blinding to clinical information, enrollment of consecutive patients, random order of measurements or simultaneous measurements with the compared methods, clear description of the evaluated population, setting, and measurement methods; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; not excessive data loss (<20%); and no obvious bias.

Grade B (moderate methodological quality) studies may be susceptible to some bias, but not sufficient to invalidate the results. Such studies do not meet the criteria described in category A. They have some deficiencies but none likely to cause major bias. Study may be missing information making assessment of the limitations and potential problems difficult.

Grade C (poor methodological quality) studies are subject to significant bias that may invalidate the results. Such studies may have serious errors in design, analysis or reporting. These studies may have large amounts of missing information or discrepancies in reporting.

Table E1 Methodological quality items for studies of type I devices

Author, Year Country (PMID) | Consecutive patients | Blinding to clinical information | Blinding to other test | Random test order or simultaneous testing | Clear description of studied population | Data loss (%) | Quality
Andreas, 1993 Germany (8425594) | YES | NS | YES | NA | NO | NA | C
Pittman, 2004 USA (15586793) | NO | NS | NO^1^ | NA | NO | 0 (?) | C

NA: Not applicable; NS: Not stated

“Only epochs scored as sleep were analyzed” (implied with Morpheus I)

Table E2 Methodological quality items for studies of type II devices

Author, Year Country (PMID) | Consecutive patients | Blinding to clinical information | Blinding to other test | Random test order or simultaneous testing | Clear description of studied population | Data loss (%) | Quality
Iber, 2004 US (15164911) | NS | YES | YES | YES | YES | ~16 | B
Gagnadoux, 2002 France (11888956) | NS | YES | YES | YES | NO | ~18 | B
Portier, 2000 France (10988088) | YES | NS | NS | YES | YES | ~34 | B
Mykytyn, 1999 Australia (9925071) | NS | NS | NS | YES | NO | 0 | C
Orr, 1993 USA (8275725) | NS | NS | NS | YES | NO | 0 | C

NS: Not stated

Table E3 Methodological quality items for studies of type III devices

Author, Year Country (PMID) | Consecutive patients | Blinding to clinical information | Blinding to other test | Random test order or simultaneous testing | Clear description of studied population | Data loss (%) | Quality
Ancoli-Israel, 1997 US (9080356) | NO | NS | NS | NO | NO | ~6 | C
Ayappa, 2004 USA (15532212) | YES | YES | YES | YES | NO | 11 | A
Ballester, 2000 Spain (8803460) | NO | NS | YES | YES | NO | 0 | B
Calleja, 2002 Spain (12503711) | NO | NO | YES^2^ | YES | NO | 8 | C
Carasco, 1996 Spain (8834345) | YES | NS | NS | YES | NO | NS | B
Claman, 2001 USA (11555758) | YES | NS | NS | YES | NO | NS | C
Dingli, 2003 UK (12608438) | YES | YES | YES | YES | YES | 3^3^, 18^4^ | A
Emsellem, 1990 US (2371595) | YES | NS | NS^5^ | YES | NO | 6 | C
Ficker, 2001 Germany (11416253) | YES | YES | YES | YES | YES | NS | A
Fietze, 2002 Germany (12097767) | NO | NS | NS | YES | YES | 0 | C
Lloberes, 1996 Spain (8977607) | NS | NS | NS | YES | NO | 0 | C
Man, 1995 Canada (7634872) | NS | NS | YES | YES | NO | 0 | B
Marrone, 2001 Italy (11980277 | YES | NS | YES | YES | NO | 0 | C
Parra, 1997 Spain (9272909) | YES | YES | YES | NO^6^ | NO | 0 | B
Quintana-Gallego, 2004 Spain (15358704 | NS | NS | YES | YES | YES | 9 | B
Redline, 1991 USA (1935282) | NS | YES | YES | YES^7^ | NO | 0 | B
Reichert 2003, USA (14592324) | YES | YES | YES | YES | YES | ~10 | B
Su, 2004 USA (15577778) | YES | NS | YES | YES | NO | 0 | B
White, 1995 USA (7792491) | NS | YES | YES | YES | NO | 0 | C
Whittle, 1997 UK (9516901) Validation trial | NO | NO | NO | NO | NO | NS | C
Verse, 2000 Germany (10858392) | NO | YES | YES | YES | YES(?) | 0 | B
Yin, 2006 Japan (16455365) | YES | NS | NS | NO | NO | 6 | C
Zucconi, 1996 Italy (8804946) | YES | NS | YES | YES | YES | 3 | A

2 Different analyst

3 Study 1

4 Study 2

5 Scoring was performed by 2 “independent” raters

6 Random order only for the first 50, the remaining 39 were first on the portable

7 Simultaneous testing in the majority (20/25) of the participants

NS: Not stated

Table E4 Methodological quality items for studies of type IV devices (all type IV devices are listed, irrespective of number of bioparameters they record)

Author, Year Country (PMID) | Consecutive patients | Blinding to clinical information | Blinding to other test | Random test order or simultaneous testing | Clear description of studied population | Data loss (%) | Quality
Adachi, 2003 Japan (14607348) | YES | NS | NS | YES | NO | 6 | C
Alvarez, 2006, Spain (16537981) | NS | NS | NS | YES | NO | NS | C^8^
Ayas, 2003 US (14592285) | NO | NS | YES | YES | YES | 0 | B
Bagnato, 2000 Brazil (10775882) | NS | NO | NS | YES | YES | 0 (?) | B
Baltzan, 2000 Canada (10678466) | NO | YES | YES | NO^9^ | NO | 8–10 | C
Bar, 2003 Israel (12628865) | YES | NS | YES | YES | YES | 0^10^ AND 3^11^ | C
Bradley, 1995 England (8553279) | YES | NS | YES | YES | NO | 0 | C^12^
Bonsignore, 1990 Italy (2278624) | NS | NS | NS | NO | NO | NS | C
Chiner 1999, Spain, 10525553 | YES | NS | NS | YES | YES | NS | B
Cooper, 1991 UK 1926029 | NS | NS | YES | NO | NO | >15 | C
Douglas, 1992 UK (1346422) | YES | NO | YES | YES | NO | NS | C
Esnaola, 1996 Spain (8980975) | YES | YES | YES | YES | YES | 1 | B
Fleury, 1996 France (8865509) | YES | NO | NO | YES | NO | >14 | C
Golpe, 2002 Spain (12377836) | NO | NS | YES | NO | NO | 7^13^ AND 33^14^ | B
Gugger, 1995 Switzerland (8553278) | YES | NS | NS | YES | NO | 0 (?) | C
Gugger, 1997 Switzerland (9072989) | YES | YES | YES | YES | NO | 2 (?) | B
Gurubhagavatula, 2004 USA (15142866) | YES | YES | YES | NS | YES | NS | B
Gyulay, 1987, Swisstzerland (3589326) | NO | NS | YES | YES | NO | 0^15^ | B
Issa, 1993 Canada (8214920) | NO | NS | NO | YES | YES | 0 | B
Kiely, 1996 Ireland (8947086) | YES | YES | YES | YES | NO | 12 | B
Koziej, 1994 Poland (7828683) | NO | NS | NO | YES | NO | 0 | C
Levy 1996, France (8620711) | YES | NS | NS | YES | NO | NO | B
Mayer, 1998 France (9817143) | YES | YES | YES | YES | YES | 0 | B
Michaelson, 2006 USA (17165661) | YES | YES | YES | YES | YES | NS | B
Overland, 2005 Norway (15988172) | YES | NS | NS | YES | NO | NS | C
Pang, 2006 USA (16890080) | YES | YES | YES | NO | YES | 18 | B
Penzel, 2004 Germany (15382839) | NS | NS | NS | YES | NO | 19 | C
Pepin 1991, USA (2019170) | NS | NS | NS | YES | YES | NO | C
Pillar, 2003 Israel (14592323) | YES | NS | YES | YES | YES | 0 | B
Pittman, 2004 USA (15453551) | NO | NS | YES | YES | NO | 0^16^ AND 3^17^ | B
Rauscher, 1993 Austria (8497828) | YES | YES | YES | YES | NO | NS | C
Rauscher, 1991 Austria (1889491) | NS | NS | NO | YES | NO | NS | C
Rees, 1998 UK (9817142) | YES | YES | NS | YES | YES(?) | 0 | C
Ryan, 1995 UK (8539678) | YES | YES | YES | NO | YES | 31 | C
Schafer, 1997 Germany 9154670 | NO | NS | YES | NO | YES | 0 | B
Series, 1993 Canada (8357109) | YES | NS | YES | NO | YES | 0 | B
Shochat, 2002 Israel, Belgium, Germany (11843310) | NS | NS | NO | YES | NO | 28 | C
Stoohs, 1992 US (1582275) | NS | YES | YES | YES | YES | NS | C^18^
Westbrook, 2005 US (16236870) | YES | NO | YES | YES | YES | ~5 | A
Williams, 1991, USA (1889245) | NS | NS | NS | NO | NO | 10 | C
Wiltshire, 2001 UK (11502633) | YES | NS | NS | NS | NO | 0 | C
van Surell, 1995 France (7656952) | YES | NS | YES | YES | NO | 0 | B^19^
Vazquez, 2000 Canada (10722770) | NO | NS | YES | YES | NO | 2 | C^20^
Zamarron, 1999 Spain (10491347) | NS | YES | YES | YES | NO | 3 | B^21^
Zamarron, 2003 Spain (12740275) | NS | YES | YES | YES | YES | ~5 | B^22^

8 The most promising finding (CMT) has data driven analysis

9 Study mentions random but explicitly states that order was based on availability of devices.

10 Home setting

11 Lab setting

12 Numbers do not corroborate

13 Group 1

14 Group 2

15 For the analyses of interest

16 Home setting

17 Lab setting

18 Correlational analyses

19 Cannot corroborate graph data with text/tables

20 They excluded all cases with difference <5 which were above and below the cutoff. Therefore, the Sens/Spec results are spuriously high

21 Correlational analyses

22 Correlational analyses

NS: Not stated