# Table of excluded studies and reasons for exclusion

The following 226 citations have been excluded after review of the full text articles. They are listed in alphabetical order (by first author’s surname).

Appendix D Table Citations of excluded publications

ID | Citation | PMID | Reason for exclusion
1 | Acebo, C., Watson, R. K., Bakos, L., and Thoman, E. B. Sleep and apnea in the elderly: reliability and validity of 24-hour recordings in the home. Sleep 1991. 14 (1):56–64. | 1811321 | (Not an eligible physiologic signal)
2 | Adams, N., Strauss, M., Schluchter, M., and Redline, S. Relation of measures of sleep-disordered breathing to neuropsychological functioning. American Journal of Respiratory & Critical Care Medicine 2001. 163 (7):1626–1631. | 11401885 | (No relevant data)
3 | Adams, T. D., Avelar, E., Cloward, T., Crosby, R. D., Farney, R. J., Gress, R., Halverson, R. C., Hopkins, P. N., Kolotkin, R. L., Lamonte, M. J., Litwin, S., Nuttall, R. T., Pendleton, R., Rosamond, W., Simper, S. C., Smith, S. C., Strong, M., Walker, J. M., Wiebke, G., Yanowitz, F. G., and Hunt, S. C. Design and rationale of the Utah obesity study. A study to assess morbidity following gastric bypass surgery. Contemporary Clinical Trials 2005. 26 (5):534–551. | 16046191 | (No relevant data)
4 | Aikens, J. E., Caruana-Montaldo, B., Vanable, P. A., Tadimeti, L., and Mendelson, W. B. MMPI correlates of sleep and respiratory disturbance in obstructive sleep apnea. Sleep 1999. 22 (3):362–369. | 10341387 | (Retrospective)
5 | Akre, H., Skatvedt, O., Oeverland, B., and Borgersen, A. K. Internal thermistors in differentiating between oral and nasal breathing during sleep. Acta Oto-Laryngologica 1999. 119 (8):934–938. | 10728937 | (No relevant data)
6 | Alchanatis, M., Paradellis, G., Pini, H., Tourkohoriti, G., and Jordanoglou, J. Left ventricular function in patients with obstructive sleep apnoea syndrome before and after treatment with nasal continuous positive airway pressure.[see comment]. Respiration 2000. 67 (4):367–371. | 10940788 | (No relevant data)
7 | Ancoli-Israel, S., Kripke, D. F., Klauber, M. R., Mason, W. J., Fell, R., and Kaplan, O. Sleep-disordered breathing in community-dwelling elderly. Sleep 1991. 14 (6):486–495. | 1798880 | (No relevant data)
8 | Anderer, P., Gruber, G., Parapatics, S., Woertz, M., Miazhynskaia, T., Klosch, G., Saletu, B., Zeitlhofer, J., Barbanoj, M. J., nker-Hopfe, H., Himanen, S. L., Kemp, B., Penzel, T., Grozinger, M., Kunz, D., Rappelsberger, P., Schlogl, A., and Dorffner, G. An E-health solution for automatic sleep classification according to Rechtschaffen and Kales: validation study of the Somnolyzer 24×7 utilizing the Siesta database. Neuropsychobiology 2005; 51(3):115–133. | 15838184 | (No relevant data)
9 | Arzt, M., Young, T., Finn, L., Skatrud ,J. B., and Bradley, T. D. Association of sleep-disordered breathing and the occurrence of stroke. Am J Respir Crit Care Med 2005; 172(11):1447–1451 | 16141444 | (No relevant data)
10 | Arzt, M., Young, T., Finn, L., Skatrud, J. B., Ryan, C. M., Newton, G. E., Mak, S., Parker, J. D., Floras, J. S., and Bradley, T. D. Sleepiness and sleep in patients with both systolic heart failure and obstructive sleep apnea. Arch Intern Med 2006. 166 (16):1716–1722. | 16983049 | (No relevant data)
11 | Aubert-Tulkens, G., Culee, C., Harmant-Van, Rijckevorsel K., and Rodenstein, D. O. Ambulatory evaluation of sleep disturbance and therapeutic effects in sleep apnea syndrome by wrist activity monitoring. American Review of Respiratory Disease 1987. 136 (4):851–856. | 3662239 | (No relevant data)
12 | Baldwin, C. M., Griffith, K. A., Nieto, F. J., O'Connor, G. T., Walsleben, J. A., and Redline, S. The association of sleep-disordered breathing and sleep symptoms with quality of life in the Sleep Heart Health Study. Sleep 2001. 24 (1):96–105. | 11204058 | (No relevant data-covered by other publication)
13 | Baldwin, C. M., Kapur, V. K., Holberg, C. J., Rosen, C., Nieto, F. J., and Sleep Heart Health Study Group. Associations between gender and measures of daytime somnolence in the Sleep Heart Health Study. Sleep 2004. 27 (2):305–311. | 15124727 | (No relevant data)
14 | Banks, S., Barnes, M., Tarquinio, N., Pierce, R. J., Lack, L. C., and McEvoy, R. D. Factors associated with maintenance of wakefulness test mean sleep latency in patients with mild to moderate obstructive sleep apnoea and normal subjects. Journal of Sleep Research 2004. 13 (1):71–78. | 14996038 | (No relevant data)
15 | Barreiro, B., Badosa. G., Quintana, S., Esteban, L., and Heredia, J. L. Comparison between automatic and manual analysis in the diagnosis of obstructive sleep apnea-hypopnea syndrome. Arch Bronconeumol 2003; 39(12):544–548 | 14636490 | (No relevant data)
16 | Becker, H., Brandenburg, U., Peter, J. H., and Von, Wichert P. Reversal of sinus arrest and atrioventricular conduction block in patients with sleep apnea during nasal continuous positive airway pressure. American Journal of Respiratory & Critical Care Medicine 1995. 151 (1):215–218. | 7812557 | (No relevant data)
17 | Berry, R. B., Koch, G. L., Trautz, S., and Wagner M. H. Comparison of respiratory event detection by a polyvinylidene fluoride film airflow sensor and a pneumotachograph in sleep apnea patients. Chest 2005; 128(3):1331–1338 | 16162726 | (No relevant data)
18 | Bixler, E. O., Vgontzas, A. N., Lin, H. M., Calhoun, S. L., Vela-Bueno, A., and Kales, A. Excessive daytime sleepiness in a general population sample: the role of sleep apnea, age, obesity, diabetes, and depression. Journal of Clinical Endocrinology & Metabolism 2005. 90 (8):4510–4515. | 15941867 | (No relevant data)
19 | Bliwise, D. L., Feldman, D. E., Bliwise, N. G., Carskadon, M. A., Kraemer, H. C., North, C. S., Petta, D. E., Seidel, W. F., and Dement, W. C. Risk factors for sleep disordered breathing in heterogeneous geriatric populations. Journal of the American Geriatrics Society 1987. 35 (2):132–141. | 3805555 | (No relevant data)
20 | Bliwise, D. L. and King, A. C. Sleepiness in clinical and nonclinical populations. Neuroepidemiology 1996. 15 (3):161–165. | 8700308 | (No relevant data)
21 | Borgel, J., Sanner, B. M., Bittlinsky, A., Keskin, F., Bartels, N. K., Buechner, N., Huesing, A., Rump, L. C., and Mugge, A. Obstructive sleep apnoea and its therapy influence high-density lipoprotein cholesterol serum levels. European Respiratory Journal 2006. 27 (1):121–127. | 16387944 | (No relevant data)
22 | Campos-Rodriguez, F., Pena-Grinan, N., Reyes-Nunez, N., Campos-Rodriguez, F., Pena-Grinan, N., Reyes-Nunez, N., De la Cruz-Moron, I; Perez-Ronchel, J., Dela, Vega-Gallardo, F., and Fernandez-Palacin, A. Mortality in obstructive sleep apnea-hypopnea patients treated with positive airway pressure. Chest 2005; 128(2):624–633 | 16100147 | (No relevant data)
23 | Can, M., Acikgoz, S., Mungan, G., Bayraktaroglu, T., Kocak, E., Guven, B., and Demirtas, S. Serum cardiovascular risk factors in obstructive sleep apnea. Chest 2006; 129(2):233–237. | 16478836 | (No relevant data)
24 | Carelli, G., Krieger, J., Calvi-Gries, F., and Macher, J. P. Periodic limb movements and obstructive sleep apneas before and after continuous positive airway pressure treatment. Journal of Sleep Research 1999. 8 (3):211–216. | 10476008 | (No relevant data-<2wk CPAP duration for B1)
25 | Carney, R. M., Howells, W. B., Freedland, K. E., Duntley, S. P., Stein, P. K., Rich, M. W., and Miller, G. E. Depression and obstructive sleep apnea in patients with coronary heart disease. Psychosomatic Medicine 2006. 68 (3):443–448. | 16738077 | (No relevant data)
26 | Chaouat, A., Weitzenblum, E., Krieger, J., Oswald, M., and Kessler, R. Pulmonary hemodynamics in the obstructive sleep apnea syndrome. Results in 220 consecutive patients.[see comment]. Chest 1996. 109 (2):380–386. | 8620709 | (No relevant data)
27 | Chervin, R. D. and Aldrich, M. S. Effects of esophageal pressure monitoring on sleep architecture.[see comment]. American Journal of Respiratory & Critical Care Medicine 1997. 156 (3:Pt 1):t-5. | 9310008 | (No relevant data)
28 | Chervin, R. D. and Aldrich, M. S. Characteristics of apneas and hypopneas during sleep and relation to excessive daytime sleepiness. Sleep 1998. 21 (8):799–806. | 9871942 | (Retrospective)
29 | Chesson, A. L., Jr., Anderson, W. M., Walls, R. C., and Bairnsfather, L. E. Assessment of hypoxemia in patients with sleep disorders using saturation impairment time. American Review of Respiratory Disease 1993. 148 (6:Pt 1):t-8. | 8256907 | (No relevant data)
30 | Chong, M. S., Ayalon, L., Marler, M., Loredo, J. S., Corey-Bloom, J., Palmer, B. W., Liu, L., and ncoli-Israel, S. Continuous positive airway pressure reduces subjective daytime sleepiness in patients with mild to moderate Alzheimer's disease with sleep disordered breathing. Journal of the American Geriatrics Society 2006. 54 (5):777–781. | 16696743 | (No relevant data)
31 | Cirignotta, F., Mondini, S., Gerardi, R., Mostacci, B., and Sancisi, E. Unreliability of automatic scoring of MESAM 4 in assessing patients with complicated obstructive sleep apnea syndrome.[see comment]. Chest 2001. 119 (5):1387–1392. | 11348943 | (N<=10 for portable vs PSG)
32 | Collop, N. A. Scoring variability between polysomnography technologists in different sleep laboratories. Sleep Med 2002; 3(1):43–47. | 14592253 | (No relevant data)
33 | Coltman, R., Taylor, D. R., Whyte, K., and Harkness, M. Craniofacial form and obstructive sleep apnea in Polynesian and Caucasian men. Sleep 2000. 23 (7):943–950. | 11083603 | (N<=100 for errors or adverse events)
34 | Cormican, L., and Williams, A. Sleep disordered breathing and its treatment in congestive heart failure. Heart 2005; 91(10):1265–1270. | 14592253 | (No relevant data)
35 | Crumley, R. L., Stein, M., Gamsu, G., Golden, J., and Dermon, S. Determination of obstructive site in obstructive sleep apnea. Laryngoscope 1987. 97 (3:Pt 1):t-8. | 3821349 | (No relevant data)
36 | Dancey, D. R., Hanly, P. J., Soong, C., Lee, B., and Hoffstein, V. Impact of menopause on the prevalence and severity of sleep apnea. Chest 2001. 120 (1):151–155. | 11451831 | (No relevant data)
37 | Dancey, D. R., Hanly, P. J., Soong, C., Lee, B., Shepard, J., Jr., and Hoffstein, V. Gender differences in sleep apnea: the role of neck circumference. Chest 2003. 123 (5):1544–1550. | 12740272 | (No relevant data)
38 | Davidson, T. M., Sedgh, J., Tran, D., and Stepnowsky, C. J., Jr. The anatomic basis for the acquisition of speech and obstructive sleep apnea: evidence from cephalometric analysis supports The Great Leap Forward hypothesis. Sleep Medicine 2005. 6 (6):497–505. | 15994120 | (No relevant data)
39 | DelCampo, F., Hornero, R., Zamarron, C., Abasolo, D. E. and Alvarez, D. Oxygen saturation regularity analysis in the diagnosis of obstructive sleep apnea. Artificial Intelligence in Medicine 2006; 37(2):111–118. | 16386411 | (Covered by other publication)
40 | Deldin, P. J., Phillips, L. K., Thomas, R. J. A preliminary study of sleep-disordered breathing in major depressive disorder. Sleep Med 2006; 7(2):131–139. | 16260180 | (No relevant data)
41 | DeZee, K. J., Jackson, J. L., Hatzigeorgiou, C., and Kristo, D.. The Epworth sleepiness scale: relationship to sleep and mental disorders in a sleep clinic. Sleep Medicine 2006; 7 (4):327–332. | 16564218 | (No relevant data)
42 | Ding, J., Nieto, F. J., Beauchamp, N. J., Jr., Harris, T. B., Robbins, J. A., Hetmanski, J. B., Fried, L. P., and Redline, S. Sleep-disordered breathing and white matter disease in the brainstem in older adults. Sleep 2004. 27 (3):474–479. | 15164901 | (Covered by other publication)
43 | Doherty, L. S., Kiely, J. L., Swan, V., and McNicholas, W. T. Long-term effects of nasal continuous positive airway pressure therapy on cardiovascular outcomes in sleep apnea syndrome. Chest 2005. 127 (6):2076–2084. | 15947323 | (No relevant data-cannot separate retrospective and prospective cohorts)
44 | Drager, L. F., Pereira, A. C., Barreto-Filho, J. A., Figueiredo, A. C., Krieger, J..E., Krieger, E. M., and Lorenzi-Filho, G. Phenotypic characteristics associated with hypertension in patients with obstructive sleep apnea. Journal of Human Hypertension 2006; 20 (7):523–528 | 16543905 | (No relevant data)
45 | Drake, C., Richardson, G., Roehrs, T., Scofield, H., and Roth, T. Vulnerability to stress-related sleep disturbance and hyperarousal. Sleep 2004. 27 (2):285–291. | 15124724 | (No relevant data)
46 | Drake, C. L., Rice, M. F., Roehrs, T. A., Rosenthal, L., Guido, P., and Roth, T. Scoring reliability of the multiple sleep latency test in a clinical population. Sleep 2000. 23 (7):911–913. | 11083600 | (No relevant data)
47 | Dreher, A., de la, Chaux R., Klemens, C., Werner, R., Baker, F., Barthlen, G., and Rasp, G. Correlation between otorhinolaryngologic evaluation and severity of obstructive sleep apnea syndrome in snorers. Archives of Otolaryngology -- Head & Neck Surgery 2005. 131 (2):95–98. | 15723938 | (No relevant data)
48 | El-Solh, A. A., Mador, M. J., Ten-Brock, E., Shucard, D. W., bul-Khoudoud, M., and Grant, B. J. Validity of neural network in sleep apnea. Sleep 1999. 22 (1):105–111. | 9989371 | (Retrospective)
49 | Elmasry, A., Lindberg, E., Hedner, J., Janson, C., and Boman, G. Obstructive sleep apnoea and urine catecholamines in hypertensive males: a population-based study. European Respiratory Journal 2002. 19 (3):511–517. | 11936531 | (No relevant data)
50 | Epstein, L. J. and Dorlac, G. R. Cost-effectiveness analysis of nocturnal oximetry as a method of screening for sleep apnea-hypopnea syndrome. Chest 1998. 113 (1):97–103. | 9440575 | (Retrospective)
51 | Fanfulla, F., Patruno, V., Bruschi, C., and Rampulla, C. Obstructive sleep apnoea syndrome: is the "half-night polysomnography" an adequate method for evaluating sleep profile and respiratory events?[see comment]. European Respiratory Journal 1997. 10 (8):1725–1729. | 9272910 | (No relevant data-not an eligible contrast)
52 | Farney, R. J., Walker, L. E., Jensen, R. L., and Walker, J. M. Ear oximetry to detect apnea and differentiate rapid eye movement (REM) and non-REM (NREM) sleep. Screening for the sleep apnea syndrome. Chest 1986. 89 (4):533–539. | 3956278 | (No relevant data-event to event comparison)
53 | Ferini-Strambi, L., Zucconi, M., Oldani, A., and Smirne, S. Heart rate variability during sleep in snorers with and without obstructive sleep apnea.[see comment]. Chest 1992. 102 (4):1023–1027. | 1395737 | (No relevant data)
54 | Fietze, I., Rottig, J., Quispe-Bravo, S., Riedel, F., Witte, J., Baumann, G., and Witt, C. Sleep apnea syndrome in patients with cardiac pacemaker. Respiration 2000. 67 (3):268–271. | 10867594 | (No relevant data)
55 | Fischer, Y., Junge-Hulsing, B., Rettinger, G., and Panis, A. The use of an ambulatory, automatic sleep recording device (QUISI version 1.0) in the evaluation of primary snoring and obstructive sleep apnoea. Clinical Otolaryngology & Allied Sciences 2004. 29 (1):18–23. | 14961847 | (No relevant data-assessed sleep staging only)
56 | Fitzpatrick, M. F., Alloway, C. E., Wakeford, T. M., MacLean, A. W., Munt, P. W., and Day, A. G. Can patients with obstructive sleep apnea titrate their own continuous positive airway pressure?[see comment]. American Journal of Respiratory & Critical Care Medicine 2003. 167 (5):716–722. | 12598214 | (No relevant data)
57 | Fleury, B., Rakotonanahary, D., Tehindrazanarivelo, A. D., Hausser-Hauw, C., and Lebeau, B. Long-term compliance to continuous positive airway pressure therapy (nCPAP) set up during a split-night polysomnography. Sleep 1994. 17 (6):512–515. | 7809564 | (No relevant data-<2wk CPAP duration for B1)
58 | Franceschi, M., Zamproni, P., Crippa, D., and Smirne, S. Excessive daytime sleepiness: a 1-year study in an unselected inpatient population. Sleep 1982. 5 (3):239–247. | 7134730 | (N<=100 for errors or adverse events)
59 | Friedman, M., Tanyeri, H., La, Rosa M., Landsberg, R., Vaidyanathan, K., Pieri, S., and Caldarelli, D. Clinical predictors of obstructive sleep apnea. Laryngoscope 1999. 109 (12):1901–1907. | 10591345 | (No relevant data)
60 | Gay, P. C., Herold, D. L., and Olson, E. J. A randomized, double-blind clinical trial comparing continuous positive airway pressure with a novel bilevel pressure system for treatment of obstructive sleep apnea syndrome. Sleep 2003. 26 (7):864–869. | 14655921 | (No relevant data)
61 | Gliklich, R. E. and Wang, P. C. Validation of the snore outcomes survey for patients with sleep-disordered breathing. Archives of Otolaryngology -- Head & Neck Surgery 2002. 128 (7):819–824. | 12117343 | (No relevant data)
62 | Goder, R., Friege, L., Fritzer, G., Strenge, H., Aldenhoff, J. B., and Hinze-Selch, D. Morning headaches in patients with sleep disorders: a systematic polysomnographic study. Sleep Medicine 2003. 4 (5):385–391. | 14592279 | (No relevant data)
63 | Golpe, R., Jimenez, A., Carpizo, R., and Cifrian, J. M. Utility of home oximetry as a screening test for patients with moderate to severe symptoms of obstructive sleep apnea. Sleep 1999. 22 (7):932–937. | 10566911 | (Retrospective)
64 | Goncalves, M. A., Paiva, T., Ramos, E., and Guilleminault, C. Obstructive sleep apnea syndrome, sleepiness, and quality of life. Chest 2004. 125 (6):2091–2096. | 15189926 | (No relevant data)
65 | Grote, L., Ploch, T., Heitmann, J., Knaack, L., Penzel, T., and Peter, J. H. Sleep-related breathing disorder is an independent risk factor for systemic hypertension. American Journal of Respiratory & Critical Care Medicine 1999. 160 (6):1875–1882. | 10588600 | (Retrospective)
66 | Guilleminault, C., Partinen, M., Hollman, K., Powell, N., and Stoohs, R. Familial aggregates in obstructive sleep apnea syndrome. Chest 1995. 107 (6):1545–1551. | 7781344 | (No relevant data)
67 | Guilleminault, C., Kirisoglu, C., and Ohayon, M. M. C-reactive protein and sleep-disordered breathing. Sleep 2004. 27 (8):1507–1511. | 15683141 | (No relevant data)
68 | Gyulay, S., Gould, D., Sawyer, B., Pond, D., Mant, A., and Saunders, N. Evaluation of a microprocessor-based portable home monitoring system to measure breathing during sleep. Sleep 1987. 10 (2):130–142. | 3589326 | (No relevant data)
69 | Gyulay, S., Olson, L. G., Hensley, M. J., King, M. T., Allen, K. M., and Saunders, N. A. A comparison of clinical assessment and home oximetry in the diagnosis of obstructive sleep apnea. American Review of Respiratory Disease 1993. 147 (1):50–53. | 8420431 | (Overt verification bias)
70 | Hashimoto, T., Ogino, H., Koga, T., and Uchimura, N. The Koga Hospital Center for studies on sleep: status report. Psychiatry & Clinical Neurosciences 2000. 54 (3):301–302. | 11186086 | (No relevant data)
71 | Herer, B., Roche, N., Carton, M., Roig, C., Poujol, V., and Huchon, G. Value of clinical, functional, and oximetric data for the prediction of obstructive sleep apnea in obese patients. Chest 1999. 116 (6):1537–1544. | 10593773 | (No relevant data)
72 | Hernandez, C., Abreu, J., Abreu, P., Colino, R., and Jimenez, A. Effects of nasal positive airway pressure treatment on oxidative stress in patients with sleep apnea-hypopnea syndrome. Arch Bronconeumol 2006; 42(3):125–129. | 16545250 | (No relevant data)
73 | Hida, W., Shindoh, C., Okabe, S., Miki, H., Kikuchi, Y., Taguchi, O., and Takishima, T. Prevalence of sleep apnea syndrome in Japanese industrial workers using a home sleep monitor. Sleep 1993. 16 (8 Suppl):S126-S127. | 8178001 | (No relevant data)
74 | Hillerdal, G., Hetta, J., Lindholm, C. E., Hultcrantz, E., and Boman, G. Symptoms in heavy snorers with and without obstructive sleep apnea. Acta Oto-Laryngologica 1991. 111 (3):574–581. | 1887783 | (No relevant data)
75 | Hoffstein, V., Rubinstein, I., Mateika, S., and Slutsky, A. S. Determinants of blood pressure in snorers. Lancet 1988. 2 (8618):992–994. | 2902495 | (No relevant data)
76 | Hoffstein, V. and Mateika, J. Evening-to-morning blood pressure variations in snoring patients with and without obstructive sleep apnea. Chest 1992. 101 (2):379–384. | 1735259 | (No relevant data)
77 | Hoffstein, V. and Szalai, J. P. Predictive value of clinical features in diagnosing obstructive sleep apnea. Sleep 1993. 16 (2):118–122. | 8446830 | (No relevant data)
78 | Hoffstein, V., Mateika, S., and Anderson, D. Snoring: is it in the ear of the beholder? Sleep 1994. 17 (6):522–526. | 7809565 | (No relevant data)
79 | Hoffstein, V. Blood pressure, snoring, obesity, and nocturnal hypoxaemia. Lancet 1994. 344 (8923):643–645. | 7915347 | (No relevant data)
80 | Hoffstein, V. and Oliver, Z. Pulmonary function and sleep apnea. Sleep & Breathing 2003. 7 (4):159–165. | 14710335 | (No relevant data)
81 | Hoflstein, V. Relationship between smoking and sleep apnea in clinic population. Sleep 2002. 25 (5):519–524. | 12150318 | (No relevant data)
82 | Howard, M. E., Desai, A. V., Grunstein, R. R., Hukins, C., Armstrong, J. G., Joffe, D., Swann, P., Campbell, D. A., and Pierce, R. J. Sleepiness, sleep-disordered breathing, and accident risk factors in commercial vehicle drivers.[see comment]. American Journal of Respiratory & Critical Care Medicine 2004. 170 (9):1014–1021. | 15317672 | (No relevant data)
83 | Hussain, S. F. and Fleetham, J. A. Overnight home oximetry: can it identify patients with obstructive sleep apnea-hypopnea who have minimal daytime sleepiness? Respiratory Medicine 2003. 97 (5):537–540. | 12735672 | (Overt verification bias)
84 | Hutter, D. A., Holland, B. K., and Ashtyani, H. Occult sleep apnea: the dilemma of negative polysomnography in symptomatic patients. Sleep Med 2004; 5(5):501–506. | 15341897 | (No relevant data)
85 | Iliescu, E. A., Lam, M., Pater, J., and Munt, P. W. Do patients with obstructive sleep apnea have clinically significant proteinuria? Clinical Nephrology 2001. 55 (3):196–204. | 11316239 | (No relevant data)
86 | Jennum, P. and Sjol, A. Self-assessed cognitive function in snorers and sleep apneics. An epidemiological study of 1,504 females and males aged 30–60 years: the Dan-MONICA II Study. European Neurology 1994. 34 (4):204–208. | 8082678 | (No relevant data)
87 | Johns, M. W. Polysomnography at a sleep disorders unit in Melbourne. Medical Journal of Australia 1991. 155 (5):303–308. | 1895972 | (No relevant data)
88 | Johnson, M. K., Carter, R., Nicol, A., Paton, R., and Banham, S. W. Long-term continuous positive airway pressure (CPAP) outcomes from a sleep service using limited sleep studies and daycase CPAP titration in the management of obstructive sleep apnoea/hypopnoea syndrome.[see comment]. Chronic Respiratory Disease 2004. 1 (2):83–88. | 16279263 | (Retrospective)
89 | Kapur, V. K., Baldwin, C. M., Resnick, H. E., Gottlieb, D. J., and Nieto, F. J. Sleepiness in patients with moderate to severe sleep-disordered breathing. Sleep 2005. 28 (4):472–477. | 16171292 | (Covered by other publication)
90 | Katsantonis, G. P., Schweitzer, P. K., Branham, G. H., Chambers, G., and Walsh, J. K. Management of obstructive sleep apnea: comparison of various treatment modalities. Laryngoscope 1988. 98 (3):304–309. | 3278184 | (Retrospective)
91 | Katz, I., Zamel, N., Slutsky, A. S., Rebuck, A. S., and Hoffstein, V. An evaluation of flow-volume curves as a screening test for obstructive sleep apnea. Chest 1990. 98 (2):337–340. | 2198137 | (No relevant data)
92 | Keenan, S. P., Anderson, B., Wiggs, B., Ryan, C. F., and Fleetham, J. A. The predictive accuracy of home oximetry in patients with suspected obstructive sleep apnea. Sleep 1993. 16 (8:Suppl):Suppl-4. | 8178005 | (No relevant data)
93 | Kessler, R., Weitzenblum, E., Chaouat, A., Iamandi, C., and Alliotte, T. Evaluation of unattended automated titration to determine therapeutic continuous positive airway pressure in patients with obstructive sleep apnea. Chest 2003. 123 (3):704–710. | 12628866 | (No relevant data-<2wk CPAP duration for B1)
94 | Kim, H. N., Vorona, R. D., Winn, M. P., Doviak, M., Johnson, D. A., and Ware, J. C. Symptoms of gastro-oesophageal reflux disease and the severity of obstructive sleep apnoea syndrome are not related in sleep disorders center patients. Alimentary Pharmacology & Therapeutics 2005. 21 (9):1127–1133. | 15854175 | (No relevant data)
95 | Kinebuchi, S., Kazama, J. J., Satoh, M., Sakai, K., Nakayama, H., Yoshizawa, H., Narita, I., Suzuki, E., and Gejyo, F. Short-term use of continuous positive airway pressure ameliorates glomerular hyperfiltration in patients with obstructive sleep apnoea syndrome. Clinical Science 2004. 107 (3):317–322. | 15191364 | (No relevant data-<2wk CPAP duration for B1)
96 | Kingshott, R. N., Engleman, H. M., Deary, I. J., and Douglas, N. J. Does arousal frequency predict daytime function?[see comment]. European Respiratory Journal 1998. 12 (6):1264–1270. | 9877475 | (No relevant data)
97 | Koehler, U., Becker, H. F., Grimm, W., Heitmann, J., Peter, J. H., and Schafer, H. Relations among hypoxemia, sleep stage, and bradyarrhythmia during obstructive sleep apnea. American Heart Journal 2000. 139 (1:Pt 1):t-8. | 10618575 | (No relevant data)
98 | Kokturk, O., Ciftci, T. U., Mollarecep, E., and Ciftci, B. Elevated C-reactive protein levels and increased cardiovascular risk in patients with obstructive sleep apnea syndrome. International Heart Journal 2005. 46 (5):801–809. | 16272771 | (No relevant data)
99 | Kokturk, O., Ciftci, T. U., Mollarecep, E., and Ciftci, B. Serum homocysteine levels and cardiovascular morbidity in obstructive sleep apnea syndrome. Respiratory Medicine 2006; 100 (3):536–541. | 16024243 | (No relevant data)
100 | Konermann, M., Sanner, B. M., Vyleta, M., Laschewski, F., Groetz, J., Sturm, A., and Zidek, W. Use of conventional and self-adjusting nasal continuous positive airway pressure for treatment of severe obstructive sleep apnea syndrome: a comparative study. Chest 1998. 113 (3):714–718. | 9515848 | (No relevant data)
101 | Krieger, J., Sforza, E., Petiau, C., and Weiss, T. Simplified diagnostic procedure for obstructive sleep apnoea syndrome: lower subsequent compliance with CPAP. European Respiratory Journal 1998. 12 (4):776–779. | 9817144 | (Retrospective)
102 | Kripke, D. F., Jean-Louis, G., Elliott, J. A., Klauber, M. R., Rex, K. M., Tuunainen, A., and Langer, R. D. Ethnicity, sleep, mood, and illumination in postmenopausal women. BMC Psychiatry 2004. 4:8 | 15070419 | (No relevant data)
103 | Kushida, C. A., Efron, B., and Guilleminault, C. A predictive morphometric model for the obstructive sleep apnea syndrome. Annals of Internal Medicine 1997. 127 (8:Pt 1):t-7. | 9341055 | (No relevant data)
104 | Lam, J. C., Lam, B., Lam, C. L., Fong, D., Wang, J. K., Tse, H.F., Lam, K. S., and Ip, M. S. Obstructive sleep apnea and the metabolic syndrome in community-based Chinese adults in Hong Kong. Respiratory Medicine 2006; 100 (6):980–987. | 16337115 | (No relevant data)
105 | Lauretano, A. M., Khosla, R. K., Richardson, G., Matheson, J., Weiss, J. W., Graham, C., and Fried, M. P. Efficacy of laser-assisted uvulopalatoplasty. Lasers in Surgery & Medicine 1997. 21 (2):109–116. | 9261787 | (No relevant data)
106 | Le Bon ,O., Hoffmann, G., Tecco, J., Staner, L., Noseda, A., Pelc, I., Linkowski, P. Mild to moderate sleep respiratory events: one negative night may not be enough. Chest 2000; 118(2):353–359. | 10936124 | (No relevant data)
107 | Lentini, S., Manka, R., Scholtyssek, S., Stoffel-Wagner, B., Luderitz, B. and Tasci,S. Creatine phosphokinase elevation in obstructive sleep apnea syndrome: an unknown association? Chest 2006. 129 (1):88–94 | 16424417 | (No relevant data)
108 | Lettieri CJ, Eliasson AH, Andrada T, Khramtsov A, Kristo DA. Does zolpidem enhance the yield of polysomnography? J Clin Sleep Med 2005; 1(2):129–131. | 15561625 | (Retrospective)
109 | Levy, A. P., Zhang, L., Miller-Lotan, R., Redline, S., O'Connor, G. T., Quan, S. F., and Resnick, H. E. Haptoglobin phenotype, sleep-disordered breathing, and the prevalence of cardiovascular disease: the Sleep Heart Health Study. Sleep 2005. 28 (2):207–213. | 16171245 | (Covered by other publication)
110 | Liesching, T. N., Carlisle, C., Marte, A., Bonitati, A., and Millman, R. P. Evaluation of the accuracy of SNAP technology sleep sonography in detecting obstructive sleep apnea in adults compared to standard polysomnography.[see comment]. Chest 2004. 125 (3):886–891. | 15006946 | (Retrospective)
111 | Lin, I. F., Chuang, M. L., Liao, Y. F., Chen, N. H., and Li, H. Y. Predicting effective continuous positive airway pressure in Taiwanese patients with obstructive sleep apnea syndrome. Journal of the Formosan Medical Association 2003. 102 (4):215–221. | 12833183 | (No relevant data)
112 | Littner, M., Hirshkowitz, M., Davila, D., Anderson, W. M., Kushida, C. A., Woodson, B. T., Johnson, S. F., Merrill, S. W., and Standards of Practice Committee of the American Academy of Sleep Medicine. Practice parameters for the use of auto-titrating continuous positive airway pressure devices for titrating pressures and treating adult patients with obstructive sleep apnea syndrome. An American Academy of Sleep Medicine report. Sleep 2002. 25 (2):143–147. | 11902424 | (No relevant data)
113 | Littner, M. R. Portable monitoring in the diagnosis of the obstructive sleep apnea syndrome. [Review] [64 refs]. Seminars in Respiratory & Critical Care Medicine 2005. 26 (1):56–67. | 16052418 | (No relevant data)
114 | Lloberes, P., Levy, G., Descals, C., Sampol, G., Roca, A., Sagales, T., and de, la Calzada. Self-reported sleepiness while driving as a risk factor for traffic accidents in patients with obstructive sleep apnoea syndrome and in non-apnoeic snorers. Respiratory Medicine 2000. 94 (10):971–976. | 11059950 | (No relevant data)
115 | Lloberes, P., Sampol, G., Levy, G., Aristizabal, D., Sagales, T., De la, Calzada M., Roca, A., Canas, I., and Morell, F. Influence of setting on unattended respiratory monitoring in the sleep apnoea/hypopnoea syndrome. European Respiratory Journal 2001. 18 (3):530–534. | 11589351 | (No relevant data-not an eligible contrast)
116 | Lofaso, F., Coste, A., Gilain, L., Harf, A., Guilleminault, C., and Goldenberg, F. Sleep fragmentation as a risk factor for hypertension in middle-aged nonapneic snorers. Chest 1996. 109 (4):896–900. | 8635367 | (No relevant data)
117 | Lojander, J., Salmi, T., and Maasilta, P. Reproducibility of oximetry with a static charge-sensitive bed in evaluation of obstructive sleep apnoea. Clinical Physiology 1998. 18 (3):225–233. | 9649910 | (No relevant data)
118 | Magalang, U. J., Dmochowski, J., Veeramachaneni, S., Draw, A., Mador, M. J., El-Solh, A., and Grant, B. J. Prediction of the apnea-hypopnea index from overnight pulse oximetry.[see comment]. Chest 2003. 124 (5):1694–1701. | 14605037 | (No relevant data)
119 | Makino, S., Handa, H., Suzukawa, K., Fujiwara, M., Nakamura, M., Muraoka, S., Takasago, I., Tanaka, Y., Hashimoto, K., and Sugimoto, T. Obstructive sleep apnoea syndrome, plasma adiponectin levels, and insulin resistance. Clinical Endocrinology 2006. 64 (1):12–19. | 16402923 | (No relevant data)
120 | Marin, J. M., Carrizo, S. J., Vicente, E., Agusti, A. G. Long-term cardiovascular outcomes in men with obstructive sleep apnoea-hypopnoea with or without treatment with continuous positive airway pressure: an observational study. Lancet 2005; 365(9464):1046–1053. | 15781100 | (No relevant data [for B1])
121 | Markou, N., Kanakaki, M., Myrianthefs, P., et al. Sleep-disordered breathing in nondialyzed patients with chronic renal failure. Lung 2006; 184(1):43–49. | 16598651 | (No relevant data)
122 | Martin JL, Mory AK, Alessi CA. Nighttime oxygen desaturation and symptoms of sleep-disordered breathing in long-stay nursing home residents. J Gerontol A Biol Sci Med Sci 2005; 60(1):104–108. | 15741291 | (No relevant data)
123 | Masa, J. F., Corral, J., Martin, M. J., Riesco, J. A., Sojo, A., Hernandez, M., and Douglas, N. J. Assessment of thoracoabdominal bands to detect respiratory effort-related arousal. European Respiratory Journal 2003. 22 (4):661–667. | 14582921 | (N<=100 for errors or adverse events)
124 | Masa, J. F., Jimenez, A., Duran, J., Capote, F., Monasterio, C., Mayos, M., Teran, J., Hernandez, L., Barbe, F., Maimo, A., Rubio, M., and Montserrat, J. M. Alternative methods of titrating continuous positive airway pressure: a large multicenter study. American Journal of Respiratory & Critical Care Medicine 2004. 170 (11):1218–1224. | 15282204 | (No relevant data)
125 | McArdle, N. and Douglas, N. J. Effect of continuous positive airway pressure on sleep architecture in the sleep apnea-hypopnea syndrome: a randomized controlled trial. American Journal of Respiratory & Critical Care Medicine 2001. 164 (8:Pt 1):t-63. | 11704596 | (No relevant data)
126 | Means, M. K., Edinger, J. D., and Husain, A. M. CPAP compliance in sleep apnea patients with and without laboratory CPAP titration. Sleep & Breathing 2004. 8 (1):7–14. | 15026934 | (No relevant data)
127 | Mehra, R., Storfer-Isser, A., Kirchner, H. L., Johnson, N., Jenny, N., Tracy, R. P., and Redline, S. Soluble interleukin 6 receptor: A novel marker of moderate to severe sleep-related breathing disorder. Archives of Internal Medicine 2006; 166 (16):1725–1731. | 16983050 | (No relevant data)
128 | Meslier, N., Gagnadoux, F., Giraud, P., Person, C., Ouksel, H., Urban, T., and Racineux, J. L. Impaired glucose-insulin metabolism in males with obstructive sleep apnoea syndrome. European Respiratory Journal 2003. 22 (1):156–160. | 12882466 | (No relevant data)
129 | Metes, A., Ohki, M., Cole, P., Haight, J. S., and Hoffstein, V. Snoring, apnea and nasal resistance in men and women. Journal of Otolaryngology 1991. 20 (1):57–61. | 2030540 | (No relevant data)
130 | Meurice, J. C., Marc, I., and Series, F. Efficacy of auto-CPAP in the treatment of obstructive sleep apnea/hypopnea syndrome. American Journal of Respiratory & Critical Care Medicine 1996. 153 (2):794–798. | 8564134 | (No relevant data)
131 | Mojon, D. S., Hess, C. W., Goldblum, D., Fleischhauer, J., Koerner, F., Bassetti, C., and Mathis, J. High prevalence of glaucoma in patients with sleep apnea syndrome.[see comment]. Ophthalmology 1999. 106 (5):1009–1012. | 10328405 | (No relevant data)
132 | Morse, C. A., Quan, S. F., Mays, M. Z., Green, C., Stephen, G., and Fass, R. Is there a relationship between obstructive sleep apnea and gastroesophageal reflux disease? Clinical Gastroenterology & Hepatology 2004. 2 (9):761–768. | 15354276 | (No relevant data)
133 | Mulgrew, A.T., Fox, N., Ayas, N.T. and Ryan, C.F. Diagnosis and initial management of obstructive sleep apnea without polysomnography: a randomized validation study. Annals of Internal Medicine 2007; 146(3):157–166. | 17283346 | (No relevant data)
134 | Munoz R, Duran-Cantolla J, Martinez-Vila E, et al. Severe sleep apnea and risk of ischemic stroke in the elderly. Stroke 2006; 37(9):2317–2321. | 16888274 | (No relevant data)
135 | Nakajima, T., Hayama, T., Ohkushi, T., Nagatomo, M., Ohkawa, T., Ohta, F., Matsuwaki, Y., Asaka, D., Chiba, S., and Endo, M. Approach to obstructive sleep apnea syndrome at Tokyo Dental College, Ichikawa General Hospital. Bulletin of Tokyo Dental College 2004. 45 (3):181–187. | 15779461 | (No relevant data)
136 | Nakano, H., Hayashi, M., Ohshima, E., Nishikata, N., and Shinohara, T. Validation of a new system of tracheal sound analysis for the diagnosis of sleep apnea-hypopnea syndrome. Sleep 2004. 27 (5):951–957. | 15453554 | (Retrospective)
137 | Nakano, H., Ikeda, T., Hayashi, M., Ohshima, E., Itoh, M., Nishikata, N., and Shinohara, T. Effect of body mass index on overnight oximetry for the diagnosis of sleep apnea. Respiratory Medicine 2004. 98 (5):421–427. | 15139571 | (Retrospective)
138 | Nieto, F. J., Young, T. B., Lind, B. K., Shahar, E., Samet, J. M., Redline, S., D'Agostino, R. B., Newman, A. B., Lebowitz, M. D., and Pickering, T. G. Association of sleep-disordered breathing, sleep apnea, and hypertension in a large community-based study. Sleep Heart Health Study. JAMA 2000. 283 (14):1829–1836. | 10770144 | (No relevant data)
139 | Nieto, F. J., Herrington, D. M., Redline, S., Benjamin, E. J., and Robbins, J. A. Sleep apnea and markers of vascular endothelial function in a large community sample of older adults.[see comment]. American Journal of Respiratory & Critical Care Medicine 2004. 169 (3):354–360. | 14551166 | (No relevant data-covered by other publication)
140 | Norman RG, Pal I, Stewart C, Walsleben JA, Rapoport DM. Interobserver agreement among sleep scorers from different centers in a large dataset. Sleep 2000; 23(7):901–908. | 16888274 | (No relevant data)
141 | Noseda, A., Kempenaers, C., Kerkhofs, M., Braun, S., Linkowski, P., and Jann, E. Constant vs auto-continuous positive airway pressure in patients with sleep apnea hypopnea syndrome and a high variability in pressure requirement. Chest 2004. 126 (1):31–37. | 15249439 | (No relevant data)
142 | Nuckton, T. J., Glidden, D. V., Browner, W. S., and Claman, D. M. Physical examination: Mallampati score as an independent predictor of obstructive sleep apnea. Sleep 2006; 29 (7):903–908. | 16895257 | (No relevant data)
143 | Oksenberg, A., Arons, E., and Froom, P. Does the severity of obstructive sleep apnea predict patients requiring high continuous positive airway pressure? Laryngoscope 2006. 116 (6):951–955. | 16735905 | (<2wk CPAP duration for B1-retrospective)
144 | Oksenberg, A., Froom, P., and Melamed, S.. Dry mouth upon awakening in obstructive sleep apnea. Journal of Sleep Research 2006; 15 (3):317–320. | 16911034 | (No relevant data)
145 | Olson, L. G., Ambrogetti, A., and Gyulay, S. G. Prediction of sleep-disordered breathing by unattended overnight oximetry. Journal of Sleep Research 1999. 8 (1):51–55. | 10188136 | (Retrospective)
146 | Ong, K. C. and Clerk, A. A. Comparison of the severity of sleep-disordered breathing in Asian and Caucasian patients seen at a sleep disorders center. Respiratory Medicine 1998. 92 (6):843–848. | 9850368 | (No relevant data)
147 | Ovesen, J., Nielsen, P. W., Clausen, J., Petri, N., and Wildschiodtz, G. Computerized apnea detection in ambulatory sleep recording with the Somnolog system. Acta Oto-Laryngologica Supplement 1992. 492:113–114. | 1632232 | (No relevant data)
148 | Parra O, Arboix A, Montserrat JM, et al. Sleep-related breathing disorders: impact on mortality of cerebrovascular disease. Eur Respir J 2004; 24(2):267–272. | 15332396 | (No relevant data)
149 | Peker Y, Hedner J, Kraiczi H, Loth S. Respiratory disturbance index: an independent predictor of mortality in coronary artery disease. Am J Respir Crit Care Med 2000; 162(1):81–86. | 10903224 | (No relevant data)
150 | Pelletier-Fleury, N., Gagnadoux, F., Philippe, C., Rakotonanahary, D., Lanoe, J. L., and Fleury, B. A cost-minimization study of telemedicine. The case of telemonitored polysomnography to diagnose obstructive sleep apnea syndrome. International Journal of Technology Assessment in Health Care 2001. 17 (4):604–611. | 11758304 | (No relevant data)
151 | Peppard, P. E., Young, T., Palta, M., and Skatrud, J. Prospective study of the association between sleep-disordered breathing and hypertension. N.Engl.J Med. 2000. 342 (19):1378–1384. | 10805822 | (No relevant data)
152 | Peppard, P. E. and Young, T. Exercise and sleep-disordered breathing: an association independent of body habitus. Sleep 2004. 27 (3):480–484. | 15164902 | (No relevant data)
153 | Pillar, G., Bar, A., Shlitner, A., Schnall, R., Shefy, J., and Lavie, P. Autonomic arousal index: an automated detection based on peripheral arterial tonometry. Sleep 2002. 25 (5):543–549. | 12150321 | (N<=100 for errors or adverse events)
154 | Planes, C., D'Ortho, M. P., Foucher, A., Berkani, M., Leroux, K., Essalhi, M., Delclaux, C., Quera-Salva, M. A., and Lofaso, F. Efficacy and cost of home-initiated auto-nCPAP versus conventional nCPAP. Sleep 2003. 26 (2):156–160. | 12683473 | (No relevant data)
155 | Polo-Kantola, P., Rauhala, E., Helenius, H., Erkkola, R., Irjala, K., and Polo, O. Breathing during sleep in menopause: a randomized, controlled, crossover trial with estrogen therapy. Obstetrics & Gynecology 2003. 102 (1):68–75. | 12850609 | (N<=100 for errors or adverse events)
156 | Polo, O., Brissaud, L., Sales, B., Besset, A., and Billiard, M. The validity of the static charge sensitive bed in detecting obstructive sleep apnoeas. European Respiratory Journal 1988. 1 (4):330–336. | 3396673 | (Not an eligible physiologic signal)
157 | Pradhan, P. S., Gliklich, R. E., and Winkelman, J. Screening for obstructive sleep apnea in patients presenting for snoring surgery.[erratum appears in Laryngoscope 1997 Jan;107(1):149]. Laryngoscope 1996. 106 (11):1393–1397. | 8914907 | (No relevant data)
158 | Punjabi, N. M., O'Hearn, D. J., Neubauer, D. N., Nieto, F. J., Schwartz, A. R., Smith, P. L., and Bandeen-Roche, K. Modeling hypersomnolence in sleep-disordered breathing. A novel approach using survival analysis. American Journal of Respiratory & Critical Care Medicine 1999. 159 (6):1703–1709. | 10351907 | (Retrospective)
159 | Punjabi, N. M., Shahar, E., Redline, S., Gottlieb, D. J., Givelber, R., Resnick, H. E., and Sleep Heart Health Study Investigators. Sleep-disordered breathing, glucose intolerance, and insulin resistance: the Sleep Heart Health Study. American Journal of Epidemiology 2004. 160 (6):521–530. | 15353412 | (No relevant data-covered by other publication)
160 | Quan SF, Griswold ME, Iber C, et al. Short-term variablility of respiration and sleep during unattended nonlaboratory polysomnogaphy--the Sleep Heart Health Study. Sleep 2002; 25(8):843–849. | 12489889 | (No relevant data)
161 | Quintana-Gallego, E., Carmona-Bernal, C., Capote, F., Sanchez-Armengol, A., Botebol-Benhamou, G., Polo-Padillo, J., and Castillo-Gomez, J. Gender differences in obstructive sleep apnea syndrome: a clinical study of 1166 patients. Respiratory Medicine 2004. 98 (10):984–989. | 15481275 | (Retrospective)
162 | Raj, R. and Hirshkowitz, M. Effect of the new Medicare guideline on patient qualification for positive airway pressure therapy. Sleep Medicine 2003. 4 (1):29–33. | 14592357 | (Retrospective)
163 | Rauscher, H., Formanek, D., Popp, W. and Zwick, H. Self-reported vs measured compliance with nasal CPAP for obstructive sleep apnea. Chest 1993 103 (6):1675–1680. | 8404084 | (No relevant data)
164 | Redline, S., Tishler, P. V., Hans, M. G., Tosteson, T. D., Strohl, K. P., and Spry, K. Racial differences in sleep-disordered breathing in African-Americans and Caucasians.[erratum appears in Am J Respir Crit Care Med 1997 May;155(5):1820]. American Journal of Respiratory & Critical Care Medicine 1997. 155 (1):186–192. | 9001310 | (No relevant data)
165 | Redline, S., Kirchner, H. L., Quan, S. F., Gottlieb, D. J., Kapur, V., and Newman, A. The effects of age, sex, ethnicity, and sleep-disordered breathing on sleep architecture. Archives of Internal Medicine 2004. 164 (4):406–418. | 14980992 | (No relevant data-covered by other publication)
166 | Redline, S., Min, N. I., Shahar, E., Rapoport, D., and O'Connor, G. Polysomnographic predictors of blood pressure and hypertension: is one index best? Sleep 2005. 28 (9):1122–1130. | 16268382 | (No relevant data)
167 | Reichmuth, K. J., Austin, D., Skatrud, J. B., and Young, T. Association of sleep apnea and type II diabetes: a population-based study. American Journal of Respiratory & Critical Care Medicine 2005. 172 (12):1590–1595. | 16192452 | (No relevant data-covered by other publication)
168 | Resta, O., Foschino-Barbaro, M. P., Legari, G., Talamo, S., Bonfitto, P., Palumbo, A., Minenna, A., Giorgino, R., and De, Pergola G. Sleep-related breathing disorders, loud snoring and excessive daytime sleepiness in obese subjects. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity 2001. 25 (5):669–675. | 11360149 | (No relevant data)
169 | Resta, O., Caratozzolo, G., Pannacciulli, N., Stefano, A., Giliberti, T., Carpagnano, G. E., and De, Pergola G. Gender, age and menopause effects on the prevalence and the characteristics of obstructive sleep apnea in obesity. European Journal of Clinical Investigation 2003. 33 (12):1084–1089. | 14636291 | (No relevant data-probably retrospective)
170 | Resta, O., Foschino Barbaro, M. P., Bonfitto, P., Giliberti, T., Depalo, A., Pannacciulli, N., and De, Pergola G. Low sleep quality and daytime sleepiness in obese patients without obstructive sleep apnoea syndrome. Journal of Internal Medicine 2003. 253 (5):536–543. | 12702031 | (No relevant data)
171 | Resta, O., Bonfitto, P., Sabato, R., De, Pergola G., and Barbaro, M. P. Prevalence of obstructive sleep apnoea in a sample of obese women: effect of menopause. Diabetes, Nutrition & Metabolism - Clinical & Experimental 2004. 17 (5):296–303. | 16295052 | (No relevant data)
172 | Resta, O., Carratu, P., Depalo, A., Giliberti, T., Ardito, M., Marrone, O., and Insalaco, G. Effects of fixed compared to automatic CPAP on sleep in Obstructive Sleep Apnoea Syndrome.[see comment]. Monaldi Archives for Chest Disease 2004. 61 (3):153–156. | 15679008 | (No relevant data)
173 | Resta, O., Carratu, P., Carpagnano, G. E., Maniscalco, M., Di, Gioia G., Lacedonia, D., Giorgino, R., and De, Pergola G. Influence of subclinical hypothyroidism and T4 treatment on the prevalence and severity of obstructive sleep apnoea syndrome (OSAS). Journal of Endocrinological Investigation 2005. 28 (10):893–898. | 16419491 | (No relevant data)
174 | Rice k, Nelson K, Rubins J, Arjes S. Unattended cardiopulmonary sleep studies to diagnose obstructive sleep apnea. Federal Practitioner 2006;16–30. | [does not have a PMID – not indexed] | (No relevant data)
175 | Roche, F., Gaspoz, J. M., Court-Fortune, Minini, P., Pichot, V., Duverney, D., Costes, F., Lacour, J. R., and Barthelemy, J. C. Screening of obstructive sleep apnea syndrome by heart rate variability analysis. Circulation 1999. 100 (13):1411–1415. | 10500042 | (Not an eligible physiologic signal)
176 | Roche, F., Duverney, D., Court-Fortune, Pichot, V., Costes, F., Lacour, J. R., Antoniadis, J. A., Gaspoz, J. M., and Barthelemy, J. C. Cardiac interbeat interval increment for the identification of obstructive sleep apnea. Pacing & Clinical Electrophysiology 2002. 25 (8):1192–1199. | 12358169 | (Not an eligible physiologic signal)
177 | Roche, F., Pichot, V., Sforza, E., Court-Fortune, Duverney, D., Costes, F., Garet, M., and Barthelemy, J. C. Predicting sleep apnoea syndrome from heart period: a time-frequency wavelet analysis.[see comment]. European Respiratory Journal 2003. 22 (6):937–942. | 14680082 | (Not an eligible physiologic signal)
178 | Roche, N., Herer, B., Roig, C., and Huchon, G. Prospective testing of two models based on clinical and oximetric variables for prediction of obstructive sleep apnea. Chest 2002. 121 (3):747–752. | 11888955 | (No relevant data)
179 | Rodrigues RN, Abreu e Silva Rodrigues AA, Pratesi R, et al. Outcome of sleepiness and fatigue scores in obstructive sleep apnea syndrome patients with and without restless legs syndrome after nasal CPAP. Arq Neuropsiquiatr 2007; 65(1):54–58. | 17420827 | (No relevant data)
180 | Rodsutti, J., Hensley, M., Thakkinstian, A., D'Este, C., and Attia, J. A clinical decision rule to prioritize polysomnography in patients with suspected sleep apnea. Sleep 2004. 27 (4):694–699. | 15283004 | (No relevant data)
181 | Rollheim, J., Osnes, T., and Miljeteig, H. The sites of obstruction in OSA, identified by continuous measurements of airway pressure and flow during sleep: ambulatory versus in-hospital recordings. Clinical Otolaryngology & Allied Sciences 1999. 24 (6):502–506. | 10606997 | (No relevant data)
182 | Rowley, J. A., Tarbichi, A. G., and Badr, M. S. The use of a predicted CPAP equation improves CPAP titration success. Sleep & Breathing 2005. 9 (1):26–32. | 15785918 | (No relevant data-<2wk CPAP duration for B1)
183 | Saarelainen, S., Himanen, S. L., Hasan, J., Virkkala, J., and Koobi, T. Whole-body impedance recording--a practical method for the diagnosis of sleep apnoea. Clinical Physiology & Functional Imaging 2003. 23 (2):110–113. | 12641606 | (Not an eligible physiologic signal)
184 | Sakakibara, H., Tong, M., Matsushita, K., Hirata, M., Konishi, Y., and Suetsugu, S. Cephalometric abnormalities in non-obese and obese patients with obstructive sleep apnoea. European Respiratory Journal 1999. 13 (2):403–410. | 10065689 | (No relevant data)
185 | Salmi, T., Partinen, M., Hyyppa, M., and Kronholm, E. Automatic analysis of static charge sensitive bed (SCSB) recordings in the evaluation of sleep-related apneas. Acta Neurol.Scand. 1986. 74 (5):360–364. | 3825493 | (Not an eligible physiologic signal)
186 | Sampol, G., Munoz, X., Sagales, M. T., Marti, S., Roca, A., Dolors de la, Calzada M., Lloberes, P., and Morell, F. Long-term efficacy of dietary weight loss in sleep apnoea/hypopnoea syndrome. European Respiratory Journal 1998. 12 (5):1156–1159. | 9864013 | (No relevant data)
187 | Sanders, M. H., Black, J., Costantino, J. P., Kern, N., Studnicki, K., and Coates, J. Diagnosis of sleep-disordered breathing by half-night polysomnography. American Review of Respiratory Disease 1991. 144 (6):1256–1261. | 1741536 | (No relevant data)
188 | Sangal, R. B. and Sangal, J. M. Measurement of P300 and sleep characteristics in patients with hypersomnia: do P300 latencies, P300 amplitudes, and multiple sleep latency and maintenance of wakefulness tests measure different factors? Clinical Electroencephalography 1997. 28 (3):179–184. | 9241473 | (No relevant data)
189 | Sanner, B. M., Konermann, M., Sturm, A., Muller, H. J., and Zidek, W. Right ventricular dysfunction in patients with obstructive sleep apnoea syndrome. European Respiratory Journal 1997. 10 (9):2079–2083. | 9311506 | (No relevant data)
190 | Sanner, B. M., Zidek, W., Laschewski, F., Sevecke-Herbst, A., Sturm, A., and Doberauer, C. Prevalence of ventricular late potentials in patients with obstructive sleep apnea syndrome. Clinical Cardiology 1999. 22 (3):219–224. | 10084065 | (No relevant data)
191 | Scharf, M. B., Brannen, D. E., McDannold, M. D., and Berkowitz, D. V. Computerized adjustable versus fixed NCPAP treatment of obstructive sleep apnea. Sleep 1996. 19 (6):491–496. | 8865507 | (No relevant data)
192 | Scharf, M. B., Stover, R., McDannold, M. D., Spinner, O., Berkowitz, D. V., and Conrad, C. Outcome evaluation of long-term nasal continuous positive airway pressure therapy in obstructive sleep apnea. American Journal of Therapeutics 1999. 6 (6):293–297. | 11329112 | (No relevant data)
193 | Schenck, C. H., Milner, D. M., Hurwitz, T. D., Bundlie, S. R., and Mahowald, M. W. A polysomnographic and clinical report on sleep-related injury in 100 adult patients. American Journal of Psychiatry 1989. 146 (9):1166–1173. | 2764174 | (N<=100 for errors or adverse events)
194 | Schwartz, D. J. The pulse transit time arousal index in obstructive sleep apnea before and after CPAP. Sleep Medicine 2005. 6 (3):199–203. | 15854849 | (No relevant data)
195 | Series, F. Accuracy of an unattended home CPAP titration in the treatment of obstructive sleep apnea. American Journal of Respiratory & Critical Care Medicine 2000. 162 (1):94–97. | 10903226 | (No relevant data)
196 | Shahar, E., Whitney, C. W., Redline, S., Lee, E. T., Newman, A. B., Javier, Nieto F., O'Connor, G. T., Boland, L. L., Schwartz, J. E., and Samet, J. M. Sleep-disordered breathing and cardiovascular disease: cross-sectional results of the Sleep Heart Health Study. Am J Respir.Crit Care Med. 2001. 163 (1):19–25. | 11208620 | (No relevant data)
197 | Shepard, J. W., Jr., Garrison, M. W., Grither, D. A., and Dolan, G. F. Relationship of ventricular ectopy to oxyhemoglobin desaturation in patients with obstructive sleep apnea. Chest 1985. 88 (3):335–340. | 2411477 | (N<=100 for errors or adverse events)
198 | Shepertycky, M. R., Banno, K., and Kryger, M. H. Differences between men and women in the clinical presentation of patients diagnosed with obstructive sleep apnea syndrome.[see comment]. Sleep 2005. 28 (3):309–314. | 16173651 | (No relevant data)
199 | Sin, D. D., Fitzgerald, F., Parker, J. D., Newton, G., Floras, J. S., and Bradley, T. D. Risk factors for central and obstructive sleep apnea in 450 men and women with congestive heart failure.[see comment]. American Journal of Respiratory & Critical Care Medicine 1999. 160 (4):1101–1106. | 10508793 | (Retrospective)
200 | Steiner, S., Jax, T., Evers, S., Hennersdorf, M., Schwalen, A., and Strauer, B. E. Altered blood rheology in obstructive sleep apnea as a mediator of cardiovascular risk. Cardiology 2005. 104 (2):92–96. | 16015032 | (No relevant data)
201 | Stepnowsky CJ, Jr., Orr WC, Davidson TM. Nightly variability of sleep-disordered breathing measured over 3 nights. Otolaryngol Head Neck Surg 2004; 131(6):837–843. | 15577777 | (No relevant data)
202 | Stoohs, R. and Guilleminault, C. Investigations of an automatic screening device (MESAM) for obstructive sleep apnoea. European Respiratory Journal 1990. 3 (7):823–829. | 2261972 | (Not an eligible physiologic signal)
203 | Suzuki, T., Nakano, H., Maekawa, J., Okamoto, Y., Ohnishi, Y., Yamauchi, M., and Kimura, H. Obstructive sleep apnea and carotid-artery intima-media thickness. Sleep 2004. 27 (1):129–133. | 14998249 | (No relevant data)
204 | Svanborg, E., Larsson, H., Carlsson-Nordlander, B., and Pirskanen, R. A limited diagnostic investigation for obstructive sleep apnea syndrome. Oximetry and static charge sensitive bed. Chest 1990. 98 (6):1341–1345. | 2245672 | (Not an eligible physiologic signal)
205 | Svensson, M., Holmstrom, M., Broman, J. E., and Lindberg, E. Can anatomical and functional features in the upper airways predict sleep apnea? A population-based study in females. Acta Oto-Laryngologica 2006; 126 (6):613–620. | 16720446 | (No relevant data)
206 | Taha, B. H., Dempsey, J. A., Weber, S. M., Badr, M. S., Skatrud, J. B., Young, T. B., Jacques, A. J., and Seow, K. C. Automated detection and classification of sleep-disordered breathing from conventional polysomnography data. Sleep 1997. 20 (11):991–1001. | 9456464 | (No relevant data-event to event comparison)
207 | Tarasiuk, A., Greenberg-Dotan, S., Simon, T., Tal, A., Oksenberg, A., and Reuveni, H. Low socioeconomic status is a risk factor for cardiovascular disease among adult obstructive sleep apnea syndrome patients requiring treatment. Chest 2006. 130(3):766–773 | 16963673 | (No relevant data)
208 | Teichtahl, H., Cunnington, D., Cherry, G., and Wang, D. Scoring polysomnography respiratory events: the utility of nasal pressure and oro-nasal thermal sensor recordings. Sleep Medicine 2003. 4 (5):419–425. | 14592283 | (N<=100 for errors or adverse events)
209 | Teschler, H., Farhat, A. A., Exner, V., Konietzko, N., and Berthon-Jones, M. AutoSet nasal CPAP titration: constancy of pressure, compliance and effectiveness at 8 month follow-up. European Respiratory Journal 1997. 10 (9):2073–2078. | 9311505 | (No relevant data)
210 | Teschler, H., Wessendorf, T. E., Farhat, A. A., Konietzko, N., and Berthon-Jones, M. Two months auto-adjusting versus conventional nCPAP for obstructive sleep apnoea syndrome. European Respiratory Journal 2000. 15 (6):990–995. | 10885414 | (N<=10 for portable vs PSG)
211 | Tsai, W. H., Remmers, J. E., Brant, R., Flemons, W. W., Davies, J., and Macarthur, C. A decision rule for diagnostic testing in obstructive sleep apnea.[see comment]. American Journal of Respiratory & Critical Care Medicine 2003. 167 (10):1427–1432. | 12738600 | (N<100 for errors or adverse events)
212 | Tvinnereim, M., Mateika, S., Cole, P., Haight, J., and Hoffstein, V. Diagnosis of obstructive sleep apnea using a portable transducer catheter. American Journal of Respiratory & Critical Care Medicine 1995. 152 (2):775–779. | 7633741 | (N<=10 for portable vs PSG)
213 | Vgontzas, A. N., Tan, T. L., Bixler, E. O., Martin, L. F., Shubert, D., and Kales, A. Sleep apnea and sleep disruption in obese patients. Archives of Internal Medicine 1994. 154 (15):1705–1711. | 8042887 | (No relevant data)
214 | Waldhorn, R.E., Herrick, T.W., Nguyen, M.C., O'Donnell, A.E., Sodero,J., and Potolicchio,S.J. Long-term compliance with nasal continuous positive airway pressure therapy of obstructive sleep apnea. Chest 1990. 97 (1):33–38. | 2403899 | (Retrospective)
215 | Waldhorn, R.E. and Wood, K. Attended home titration of nasal continuous positive airway pressure therapy for obstructive sleep apnea. Chest 1993. 104 (6):1707–1710. | 8252947 | (No relevant data)
216 | White, D. P. and Gibb, T. J. Evaluation of the Healthdyne NightWatch system to titrate CPAP in the home. Sleep 1998. 21 (2):198–204. | 9542803 | (No relevant data)
217 | Whitney, C. W., Gottlieb, D. J., Redline, S., Norman, R. G., Dodge, R. R., Shahar, E., Surovec, S., and Nieto, F. J. Reliability of scoring respiratory disturbance indices and sleep staging. Sleep 1998. 21 (7):749–757. | 11286351 | (Covered by other publication)
218 | Williams, A., Santiago, S., and Stein, M. Screening for sleep apnea? Chest 1989. 96 (3):451–453. | 2788558 | (No relevant data)
219 | Yaggi HK, Concato J, Kernan WN, et al. Obstructive sleep apnea as a risk factor for stroke and death. N Engl J Med 2005; 353(19):2034–2041. | 16282178 | (No relevant data)
220 | Yamashiro, Y. and Kryger, M. H. Nocturnal oximetry: is it a screening tool for sleep disorders? Sleep 1995. 18 (3):167–171. | 7610312 | (Retrospective)
221 | Young, T., Peppard, P., Palta, M., Hla, K. M., Finn, L., Morgan, B., and Skatrud, J. Population-based study of sleep-disordered breathing as a risk factor for hypertension. Arch.Intern.Med. 1997. 157 (15):1746–1752. | 9250236 | (No relevant data)
222 | Young, T., Rabago, D., Zgierska, A., Austin, D., and Laurel, F. Objective and subjective sleep quality in premenopausal, perimenopausal, and postmenopausal women in the Wisconsin Sleep Cohort Study.[see comment]. Sleep 2003. 26 (6):667–672. | 14572118 | (No relevant data-covered by other publication)
223 | Zafar, S., Ayappa, I., Norman, R. G., Krieger, A. C., Walsleben, J. A., and Rapoport, D. M. Choice of oximeter affects apnea-hypopnea index. Chest 2005. 127 (1):80–88. | 15653966 | (No relevant data)
224 | Zamarron, C., Romero, P. V., Gude, F., Amaro, A., and Rodriguez, J. R. Screening of obstructive sleep apnoea: heart rate spectral analysis of nocturnal pulse oximetric recording. Respiratory Medicine 2001. 95 (9):759–765. | 11575898 | (Not an eligible physiologic signal)
225 | Zamarron, C., Hornero, R., del Campo, F., Abasolo, D. and Alvarez, D. Heart rate regularity analysis obtained from pulse oximetric recordings in the diagnosis of obstructive sleep apnea. Sleep & Breathing 2006; 10(2):83–89 | 16450176 | (Not an eligible physiologic signal; covered by another publication)
226 | Zou, D., Grote, L., Peker, Y., Lindblad, U., and Hedner. J. Validation a portable monitoring device for sleep apnea diagnosis in a population based cohort using synchronized home polysomnography. Sleep 2006; 29 (3):367–374. | 16553023 | (Not an eligible comparison)

B1: (refers to section B1 of the technology assessment); CPAP: Continuous positive airway pressure; ID: identification number; N: number; PMID: PubMed ID; wk: week(s)