# Table of eligible studies

The following 95 citations have been deemed eligible after full text review. They are listed in alphabetical order (by first author’s surname).

Appendix C Table Citations of included publications

ID | Citation | PMID
1. | Adachi, H., Mikami, A., Kumano-go, T., Suganuma, N., Matsumoto, H., Shigedo, Y., Sugita, Y., and Takeda, M. Clinical significance of pulse rate rise during sleep as a screening marker for the assessment of sleep fragmentation in sleep-disordered breathing.[see comment]. Sleep Medicine 2003. 4 (6):537–542. | 14607348
2. | Alvarez, D., Hornero, R., Abasolo, D., del, Campo F., and Zamarron, C. Nonlinear characteristics of blood oxygen saturation from nocturnal oximetry for obstructive sleep apnoea detection. Physiological Measurement 2006. 27 (4):399–412. | 16537981
3. | Ancoli-Israel, S., Mason, W., Coy, T. V., Stepnowsky, C., Clausen, J. L., and Dimsdale, J. Evaluation of sleep disordered breathing with unattended recording: the Nightwatch System. Journal of Medical Engineering & Technology 1997. 21 (1):10–14. | 9080356
4. | Andreas, S., von, Breska B., Magnusson, K., and Kreuzer, H. Validation of automated sleep stage and apnoea analysis in suspected obstructive sleep apnoea. European Respiratory Journal 1993. 6 (1):48–52. | 8425594
5. | Ayappa, I., Norman, R. G., Suryadevara, M., and Rapoport, D. M. Comparison of limited monitoring using a nasal-cannula flow signal to full polysomnography in sleep-disordered breathing. Sleep 2004. 27 (6):1171–1179. | 15532212
6. | Ayas, N. T., Pittman, S., MacDonald, M., and White, D. P. Assessment of a wrist-worn device in the detection of obstructive sleep apnea. Sleep Medicine 2003. 4 (5):435–442. | 14592285
7. | Bagnato, M. C., Nery, L. E., Moura, S. M., Bittencourt, L. R., and Tufik, S. Comparison of AutoSet and polysomnography for the detection of apnea-hypopnea events. Brazilian Journal of Medical & Biological Research 2000. 33 (5):515–519. | 10775882
8. | Ballester, E., Solans, M., Vila, X., Hernandez, L., Quinto, L., Bolivar, I., Bardagi, S., and Montserrat, J. M. Evaluation of a portable respiratory recording device for detecting apnoeas and hypopnoeas in subjects from a general population. European Respiratory Journal 2000. 16 (1):123–127. | 10933097
9. | Baltzan, M. A., Verschelden, P., Al-Jahdali, H., Olha, A. E., and Kimoff, R. J. Accuracy of oximetry with thermistor (OxiFlow) for diagnosis of obstructive sleep apnea and hypopnea. Sleep 2000. 23 (1):61–69. | 10678466
10. | Bar, A., Pillar, G., Dvir, I., Sheffy, J., Schnall, R. P., and Lavie, P. Evaluation of a portable device based on peripheral arterial tone for unattended home sleep studies.[see comment]. Chest 2003. 123 (3):695–703. | 12628865
11. | Bearpark, H., Elliott, L., Grunstein, R., Cullen, S., Schneider, H., Althaus, W., and Sullivan, C. Snoring and sleep apnea. A population study in Australian men. American Journal of Respiratory & Critical Care Medicine 1995. 151 (5):1459–1465. | 7735600
12. | Bennett, L. S., Langford, B. A., Stradling, J. R., and Davies, R. J. Sleep fragmentation indices as predictors of daytime sleepiness and nCPAP response in obstructive sleep apnea. Am J Respir.Crit Care Med. 1998. 158 (3):778–786. | 9731004
13. | Bonsignore, G., Marrone, O., Macaluso, C., Salvaggio, A., Stallone, A., and Bellia, V. Validation of oximetry as a screening test for obstructive sleep apnoea syndrome. European Respiratory Journal - Supplement 1990. 11:542s–544s. | 2278624
14. | Bradley, P. A., Mortimore, I. L., and Douglas, N. J. Comparison of polysomnography with ResCare Autoset in the diagnosis of the sleep apnoea/hypopnoea syndrome. Thorax 1995. 50 (11):1201–1203. | 8553279
15. | Calleja, J. M., Esnaola, S., Rubio, R., and Duran, J. Comparison of a cardiorespiratory device versus polysomnography for diagnosis of sleep apnoea. European Respiratory Journal 2002. 20 (6):1505–1510. | 12503711
16. | Carrasco, O., Montserrat, J. M., Lloberes, P., Ascasco, C., Ballester, E., Fornas, C., and Rodriguez-Roisin, R. Visual and different automatic scoring profiles of respiratory variables in the diagnosis of sleep apnoea-hypopnoea syndrome. European Respiratory Journal 1996. 9 (1):125–130. | 8834345
17. | Chiner, E., Signes-Costa, J., Arriero, J. M., Marco, J., Fuentes, I., and Sergado, A. Nocturnal oximetry for the diagnosis of the sleep apnoea hypopnoea syndrome: a method to reduce the number of polysomnographies?[see comment]. Thorax 1999. 54 (11):968–971. | 10525553
18. | Claman D, Murr A, Trotter K. Clinical validation of the Bedbugg in detection of obstructive sleep apnea. Otolaryngol Head Neck Surg 2001; 125(3):227–230.
19. | Cooper, B. G., Veale, D., Griffiths, C. J., and Gibson, G. J. Value of nocturnal oxygen saturation as a screening test for sleep apnoea. Thorax 1991. 46 (8):586–588. | 1926029
20. | d'Ortho, M. P., Grillier-Lanoir, V., Levy, P., Goldenberg, F., Corriger, E., Harf, A., and Lofaso, F. Constant vs. automatic continuous positive airway pressure therapy: home evaluation. Chest 2000. 118 (4):1010–1017. | 11035671
21. | Dingli, K., Coleman, E. L., Vennelle, M., Finch, S. P., Wraith, P. K., Mackay, T. W., and Douglas, N. J. Evaluation of a portable device for diagnosing the sleep apnoea/hypopnoea syndrome. European Respiratory Journal 2003. 21 (2):253–259. | 12608438
22. | Douglas, N. J., Thomas, S., and Jan, M. A. Clinical value of polysomnography.[see comment]. Lancet 1992. 339 (8789):347–350. | 1346422
23. | Emsellem, H. A., Corson, W. A., Rappaport, B. A., Hackett, S., Smith, L. G., and Hausfeld, J. N. Verification of sleep apnea using a portable sleep apnea screening device. Southern Medical Journal 1990. 83 (7):748–752. | 2371595
24. | Esnaola, S., Duran, J., Infante-Rivard, C., Rubio, R., and Fernandez, A. Diagnostic accuracy of a portable recording device (MESAM IV) in suspected obstructive sleep apnoea. European Respiratory Journal 1996. 9 (12):2597–2605. | 8980975
25. | Ficker JH, Wiest GH, Wilpert J, Fuchs FS, Hahn EG. Evaluation of a portable recording device (Somnocheck) for use in patients with suspected obstructive sleep apnoea. Respiration 2001; 68(3):307–312. | 11416253
26. | Fietze, I., Glos, M., Rottig, J., and Witt, C. Automated analysis of data is inferior to visual analysis of ambulatory sleep apnea monitoring. Respiration 2002. 69 (3):235–241. | 12097767
27. | Flemons, W. W., Whitelaw, W. A., Brant, R., and Remmers, J. E. Likelihood ratios for a sleep apnea clinical prediction rule. American Journal of Respiratory & Critical Care Medicine 1994. 150 (5:Pt 1):t-85. | 7952553
28. | Fleury, B., Rakotonanahary, D., Hausser-Hauw, C., Lebeau, B., and Guilleminault, C. A laboratory validation study of the diagnostic mode of the Autoset system for sleep-related respiratory disorders.[erratum appears in Sleep 1996 Sep;19(7):601]. Sleep 1996. 19 (6):502–505. | 8865509
29. | Fry, J. M., DiPhillipo, M. A., Curran, K., Goldberg, R., and Baran, A. S. Full polysomnography in the home. Sleep 1998. 21 (6):635–642. | 9779523
30. | Gagnadoux, F., Pelletier-Fleury, N., Philippe, C., Rakotonanahary, D., and Fleury, B. Home unattended vs hospital telemonitored polysomnography in suspected obstructive sleep apnea syndrome: a randomized crossover trial. Chest 2002. 121 (3):753–758. | 11888956
31. | Golpe, R., Jimenez, A., and Carpizo, R. Home sleep studies in the assessment of sleep apnea/hypopnea syndrome. Chest 2002. 122 (4):1156–1161. | 12377836
32. | Gugger, M. Comparison of ResMed AutoSet (version 3.03) with polysomnography in the diagnosis of the sleep apnoea/hypopnoea syndrome. European Respiratory Journal 1997. 10 (3):587–591. | 9072989
33. | Gugger, M., Mathis, J., and Bassetti, C. Accuracy of an intelligent CPAP machine with in-built diagnostic abilities in detecting apnoeas: a comparison with polysomnography. Thorax 1995. 50 (11):1199–1201. | 8553278
34. | Gurubhagavatula, I., Maislin, G., Nkwuo, J. E., and Pack, A. I. Occupational screening for obstructive sleep apnea in commercial drivers. American Journal of Respiratory & Critical Care Medicine 2004. 170 (4):371–376. | 15142866
35. | Gyulay, S., Gould, D., Sawyer, B., Pond, D., Mant, A., and Saunders, N. Evaluation of a microprocessor-based portable home monitoring system to measure breathing during sleep. Sleep 1987. 10 (2):130–142. | 3589326
36. | Hedner, J., Pillar, G., Pittman, S. D., Zou, D., Grote, L., and White, D. P. A novel adaptive wrist actigraphy algorithm for sleep-wake assessment in sleep apnea patients. Sleep 2004. 27 (8):1560–1566. | 15683148
37. | Hermida, R. C., Zamarron, C., Ayala, D. E., and Calvo, C. Effect of continuous positive airway pressure on ambulatory blood pressure in patients with obstructive sleep apnoea. Blood Pressure Monitoring 2004. 9 (4):193–202. | 15311146
38. | Iber, C., Redline, S., Kaplan Gilpin, A. M., Quan, S. F., Zhang, L., Gottlieb, D. J., Rapoport, D., Resnick, H. E., Sanders, M., and Smith, P. Polysomnography performed in the unattended home versus the attended laboratory setting--Sleep Heart Health Study methodology. Sleep 2004. 27 (3):536–540. | 15164911
39. | Ip, M. S., Lam, B., Tang, L. C., Lauder, I. J., Ip, T. Y., and Lam, W. K. A community study of sleep-disordered breathing in middle-aged Chinese women in Hong Kong: prevalence and gender differences. Chest 2004. 125 (1):127–134. | 14718431
40. | Issa, F. G., Morrison, D., Hadjuk, E., Iyer, A., Feroah, T., and Remmers, J. E. Digital monitoring of sleep-disordered breathing using snoring sound and arterial oxygen saturation. American Review of Respiratory Disease 1993. 148 (4:Pt 1):t-9. | 8214920
41. | Kapur, V. K., Rapoport, D. M., Sanders, M. H., Enright, P., Hill, J., Iber, C., and Romaniuk, J. Rates of sensor loss in unattended home polysomnography: the influence of age, gender, obesity, and sleep-disordered breathing. Sleep 2000. 23 (5):682–688. | 10947036
42. | Kiely, J. L., Delahunty, C., Matthews, S., and McNicholas, W. T. Comparison of a limited computerized diagnostic system (ResCare Autoset) with polysomnography in the diagnosis of obstructive sleep apnoea syndrome. European Respiratory Journal 1996. 9 (11):2360–2364. | 8947086
43. | Koziej, M., Cieslicki, J. K., Gorzelak, K., Sliwinski, P., and Zielinski, J. Hand-scoring of MESAM 4 recordings is more accurate than automatic analysis in screening for obstructive sleep apnoea. European Respiratory Journal 1994. 7 (10):1771–1775. | 7828683
44. | Levy, P., Pepin, J. L., schaux-Blanc, C., Paramelle, B., and Brambilla, C. Accuracy of oximetry for detection of respiratory disturbances in sleep apnea syndrome. Chest 1996. 109 (2):395–399. | 8620711
45. | Lloberes, P., Marti, S., Sampol, G., Roca, A., Sagales, T., Munoz, X., and Ferrer, M. Predictive factors of quality-of-life improvement and continuous positive airway pressure use in patients with sleep apnea-hypopnea syndrome: study at 1 year. Chest 2004. 126 (4):1241–1247. | 15486388
46. | Lloberes, P., Montserrat, J. M., Ascaso, A., Parra, O., Granados, A., Alonso, P., Vilaseca, I., and Rodriguez-Roisin, R. Comparison of partially attended night time respiratory recordings and full polysomnography in patients with suspected sleep apnoea/hypopnoea syndrome. Thorax 1996. 51 (10):1043–1047. | 8977607
47. | Man, G. C. and Kang, B. V. Validation of a portable sleep apnea monitoring device. Chest 1995. 108 (2):388–393. | 7634872
48. | Margel, D., Cohen, M., Livne, P. M., and Pillar, G. Severe, but not mild, obstructive sleep apnea syndrome is associated with erectile dysfunction. Urology 2004. 63 (3):545–549. | 15028455
49. | Marrone, O., Salvaggio, A., Bonsignore, M. R., Insalaco, G., and Bonsignore, G. Blood pressure responsiveness to obstructive events during sleep after chronic CPAP. European Respiratory Journal 2003. 21 (3):509–514. | 12662010
50. | Marrone, O., Salvaggio, A., Insalaco, G., Bonsignore, M. R., and Bonsignore, G. Evaluation of the POLYMESAM system in the diagnosis of obstructive sleep apnea syndrome. Monaldi Archives for Chest Disease 2001. 56 (6):486–490. | 11980277
51. | Masa, J. F., Rubio, M., and Findley, L. J. Habitually sleepy drivers have a high frequency of automobile crashes associated with respiratory disorders during sleep. American Journal of Respiratory & Critical Care Medicine 2000. 162 (4:Pt 1):t-12. | 11029353
52. | Mayer, P., Meurice, J. C., Philip-Joet, F., Cornette, A., Rakotonanahary, D., Meslier, N., Pepin, J. L., Levy, P., and Veale, D. Simultaneous laboratory-based comparison of ResMed Autoset with polysomnography in the diagnosis of sleep apnoea/hypopnoea syndrome. European Respiratory Journal 1998. 12 (4):770–775. | 9817143
53. | Mehra, R. and Strohl, K. P. Incidence of serious adverse events during nocturnal polysomnography.[see comment]. Sleep 2004. 27 (7):1379–1383. | 15586791
54. | Michaelson, P. G., Allan, P., Chaney, J., Mair, E. A. Validations of a portable home sleep study with twelve-lead polysomnography: comparisons and insights into a variable gold standard. Annals of Otology, Rhinology & Laryngology 2006; 115 (11):802–809. | 17165661
55. | Middelkoop, H. A., Knuistingh, Neven A., van Hilten, J. J., Ruwhof, C. W., and Kamphuisen, H. A. Wrist actigraphic assessment of sleep in 116 community based subjects suspected of obstructive sleep apnoea syndrome. Thorax 1995. 50 (3):284–289. | 7660344
56. | Mykytyn, I. J., Sajkov, D., Neill, A. M., and McEvoy, R. D. Portable computerized polysomnography in attended and unattended settings. Chest 1999. 115 (1):114–122. | 9925071
57. | Neven, A. K., Middelkoop, H. A., Kemp, B., Kamphuisen, H. A., and Springer, M. P. The prevalence of clinically significant sleep apnoea syndrome in The Netherlands. Thorax 1998. 53 (8):638–642. | 9828848
58. | Noseda, A., Jann, E., Hoffmann, G., Linkowski, P., and Kerkhofs, M. Compliance with nasal continuous positive airway pressure assessed with a pressure monitor: pattern of use and influence of sleep habits. Respiratory Medicine 2000. 94 (1):76–81. | 10714483
59. | Noseda, A., Kempenaers, C., Kerkhofs, M., Houben, J. J., and Linkowski, P. Sleep apnea after 1 year domiciliary nasal-continuous positive airway pressure and attempted weight reduction. Potential for weaning from continuous positive airway pressure. Chest 1996. 109 (1):138–143. | 8549176
60. | Orr, W. C., Eiken, T., Pegram, V., Jones, R., and Rundell, O. H. A laboratory validation study of a portable system for remote recording of sleep-related respiratory disorders. Chest 1994. 105 (1):160–162. | 8275725
61. | Overland, B., Bruskeland, G., Akre, H., and Skatvedt, O. Evaluation of a portable recording device (Reggie) with actimeter and nasopharyngeal/esophagus catheter incorporated. Respiration 2005. 72 (6):600–605. | 15988172
62. | Pang, K. P., Dillard, T. A., Blanchard, A. R., Gourin, C. G., Podolsky, R., and Terris, D. J. A comparison of polysomnography and the SleepStrip in the diagnosis of OSA. Otolaryngology - Head & Neck Surgery 2006; 135 (2):265–268. | 16890080
63. | Parra, O., Garcia-Esclasans, N., Montserrat, J. M., Garcia, Eroles L., Ruiz, J., Lopez, J. A., Guerra, J. M., and Sopena, J. J. Should patients with sleep apnoea/hypopnoea syndrome be diagnosed and managed on the basis of home sleep studies?[see comment]. European Respiratory Journal 1997. 10 (8):1720–1724. | 9272909
64. | Penzel, T., Kesper, K., Pinnow, I., Becker, H. F., and Vogelmeier, C. Peripheral arterial tonometry, oximetry and actigraphy for ambulatory recording of sleep apnea. Physiological Measurement 2004. 25 (4):1025–1036. | 15382839
65. | Pepin, J. L., Levy, P., Lepaulle, B., Brambilla, C., and Guilleminault, C. Does oximetry contribute to the detection of apneic events? Mathematical processing of the SaO2 signal. Chest 1991. 99 (5):1151–1157. | 2019170
66. | Pillar, G., Bar, A., Betito, M., Schnall, R. P., Dvir, I., Sheffy, J., and Lavie, P. An automatic ambulatory device for detection of AASM defined arousals from sleep: the WP100. Sleep Medicine 2003. 4 (3):207–212. | 14592323
67. | Pittman, S. D., Ayas, N. T., MacDonald, M. M., Malhotra, A., Fogel, R. B., and White, D. P. Using a wrist-worn device based on peripheral arterial tonometry to diagnose obstructive sleep apnea: in-laboratory and ambulatory validation. Sleep 2004. 27 (5):923–933. | 15453551
68. | Pittman, S. D., MacDonald, M. M., Fogel, R. B., Malhotra, A., Todros, K., Levy, B., Geva, A. B., and White, D. P. Assessment of automated scoring of polysomnographic recordings in a population with suspected sleep-disordered breathing. Sleep 2004. 27 (7):1394–1403. | 15586793
69. | Portier, F., Portmann, A., Czernichow, P., Vascaut, L., Devin, E., Benhamou, D., Cuvelier, A., and Muir, J. F. Evaluation of home versus laboratory polysomnography in the diagnosis of sleep apnea syndrome. American Journal of Respiratory & Critical Care Medicine 2000. 162 (3:Pt 1):t-8. | 10988088
70. | Quintana-Gallego, E., Villa-Gil, M., Carmona-Bernal, C., Botebol-Benhamou, G., Martinez-Martinez, A., Sanchez-Armengol, A., Polo-Padillo, J., and Capote, F. Home respiratory polygraphy for diagnosis of sleep-disordered breathing in heart failure. European Respiratory Journal 2004. 24 (3):443–448. | 15358704
71. | Rauscher, H., Popp, W., and Zwick, H. Quantification of sleep disordered breathing by computerized analysis of oximetry, heart rate and snoring. European Respiratory Journal 1991. 4 (6):655–659. | 1889491
72. | Rauscher, H., Popp, W., and Zwick, H. Model for investigating snorers with suspected sleep apnoea. Thorax 1993. 48 (3):275–279. | 8497828
73. | Redline, S., Tosteson, T., Boucher, M. A., and Millman, R. P. Measurement of sleep-related breathing disturbances in epidemiologic studies. Assessment of the validity and reproducibility of a portable monitoring device. Chest 1991. 100 (5):1281–1286. | 1935282
74. | Rees, K., Wraith, P. K., Berthon-Jones, M., and Douglas, N. J. Detection of apnoeas, hypopnoeas and arousals by the AutoSet in the sleep apnoea/hypopnoea syndrome. European Respiratory Journal 1998. 12 (4):764–769. | 9817142
75. | Reichert, J. A., Bloch, D. A., Cundiff, E., and Votteri, B. A. Comparison of the NovaSom QSG, a new sleep apnea home-diagnostic system, and polysomnography. Sleep Medicine 2003. 4 (3):213–218. | 14592324
76. | Ryan, P. J., Hilton, M. F., Boldy, D. A., Evans, A., Bradbury, S., Sapiano, S., Prowse, K., and Cayton, R. M. Validation of British Thoracic Society guidelines for the diagnosis of the sleep apnoea/hypopnoea syndrome: can polysomnography be avoided? Thorax 1995. 50 (9):972–975. | 8539678
77. | Schafer, H., Ewig, S., Hasper, E., and Luderitz, B. Predictive diagnostic value of clinical assessment and nonlaboratory monitoring system recordings in patients with symptoms suggestive of obstructive sleep apnea syndrome. Respiration 1997. 64 (3):194–199. | 9154670
78. | Series, F. and Marc, I. Nasal pressure recording in the diagnosis of sleep apnoea hypopnoea syndrome.[see comment]. Thorax 1999. 54 (6):506–510. | 10335004
79. | Series, F., Marc, I., Cormier, Y., and La, Forge J. Utility of nocturnal home oximetry for case finding in patients with suspected sleep apnea hypopnea syndrome.[see comment]. Annals of Internal Medicine 1993. 119 (6):449–453. | 8357109
80. | Shochat, T., Hadas, N., Kerkhofs, M., Herchuelz, A., Penzel, T., Peter, J. H., and Lavie, P. The SleepStrip: an apnoea screener for the early detection of sleep apnoea syndrome. European Respiratory Journal 2002. 19 (1):121–126. | 11843310
81. | Stoohs, R. and Guilleminault, C. MESAM 4: an ambulatory device for the detection of patients at risk for obstructive sleep apnea syndrome (OSAS). Chest 1992. 101 (5):1221–1227. | 1582275
82. | Su, S., Baroody, F. M., Kohrman, M., and Suskind, D. A comparison of polysomnography and a portable home sleep study in the diagnosis of obstructive sleep apnea syndrome. Otolaryngology - Head & Neck Surgery 2004. 131 (6):844–850. | 15577778
83. | Van Surell C., Lemaigre, D., Leroy, M., Foucher, A., Hagenmuller, M. P., and Raffestin, B. Evaluation of an ambulatory device, CID 102, in the diagnosis of obstructive sleep apnoea syndrome. European Respiratory Journal 1995. 8 (5):795–800. | 7656952
84. | Vazquez, J. C., Tsai, W. H., Flemons, W. W., Masuda, A., Brant, R., Hajduk, E., Whitelaw, W. A., and Remmers, J. E. Automated analysis of digital oximetry in the diagnosis of obstructive sleep apnoea. Thorax 2000. 55 (4):302–307. | 10722770
85. | Verse, T., Pirsig, W., Junge-Hulsing, B., and Kroker, B. Validation of the POLY-MESAM seven-channel ambulatory recording unit. Chest 2000. 117 (6):1613–1618. | 10858392
86. | Westbrook, P. R., Levendowski, D. J., Cvetinovic, M., Zavora, T., Velimirovic, V., Henninger, D., and Nicholson, D. Description and validation of the apnea risk evaluation system: a novel method to diagnose sleep apnea-hypopnea in the home. Chest 2005. 128 (4):2166–2175. | 16236870
87. | White, D. P., Gibb, T. J., Wall, J. M., and Westbrook, P. R. Assessment of accuracy and analysis time of a novel device to monitor sleep and breathing in the home.[see comment]. Sleep 1995. 18 (2):115–126. | 7792491
88. | Whitelaw, W. A., Brant, R. F., and Flemons, W. W. Clinical usefulness of home oximetry compared with polysomnography for assessment of sleep apnea.[see comment]. American Journal of Respiratory & Critical Care Medicine 2005. 171 (2):188–193. | 15486338
89. | Whittle, A. T., Finch, S. P., Mortimore, I. L., Mackay, T. W., and Douglas, N. J. Use of home sleep studies for diagnosis of the sleep apnoea/hypopnoea syndrome. Thorax 1997. 52 (12):1068–1073. | 9516901
90. | Williams, A. J., Yu, G., Santiago, S., and Stein, M. Screening for sleep apnea using pulse oximetry and a clinical score. Chest 1991. 100 (3):631–635. | 1889245
91. | Wiltshire, N., Kendrick, A. H., and Catterall, J. R. Home oximetry studies for diagnosis of sleep apnea/hypopnea syndrome: limitation of memory storage capabilities. Chest 2001. 120 (2):384–389. | 11502633
92. | Yin, M., Miyazaki, S., and Ishikawa, K. Evaluation of type 3 portable monitoring in unattended home setting for suspected sleep apnea: factors that may affect its accuracy. Otolaryngology - Head & Neck Surgery 2006. 134 (2):204–209. | 16455365
93. | Zamarron, C., Gude, F., Barcala, J., Rodriguez, J. R., and Romero, P. V. Utility of oxygen saturation and heart rate spectral analysis obtained from pulse oximetric recordings in the diagnosis of sleep apnea syndrome. Chest 2003. 123 (5):1567–1576. | 12740275
94. | Zamarron, C., Romero, P. V., Rodriguez, J. R., and Gude, F. Oximetry spectral analysis in the diagnosis of obstructive sleep apnoea. Clinical Science 1999. 97 (4):467–473. | 10491347
95. | Zucconi, M., Ferini-Strambi, L., Castronovo, V., Oldani, A., and Smirne, S. An unattended device for sleep-related breathing disorders: validation study in suspected obstructive sleep apnoea syndrome. European Respiratory Journal 1996. 9 (6):1251–1256. | 8804946