# Data extraction forms used in the technology assessment

The generic data extraction form and the data extraction form for studies that were assessed for errors, data loss, harms and adverse events are shown in the following pages.

## Generic data extraction form

A. Study description and applicability to Medicare population

Author, Year Country (UI) | N_tot_ | Mean age (Range) | ~%≥65 yr | Male (%) | Sampling population^A^ | Recruitment method^B^ | Eligibility criteria

A Patients representative of the general population? Patients referred to a specialized center? [However defined] high-risk patients?

B Consecutive patients, random sampling, case series/convenience sample

B. Participant characteristics and baseline “severity/risk”

Author, Year Country (UI) | Mean BMI (Range) | Mean PSG AHI [RDI] (Range) | PSG AHI ≥15 [RDI≥15] (%) | COPD (%) | Symptoms^A^ (%) | Comorbidities

A Day fatigue and somnolence; or other obstructive-sleep apnea (OSA)-related, as characterized by authors

AHI: Apnea-hypopnea index; PSG: Polysomnography (facility-based); RDI: respiratory distress index

C. Description of facility-based polysomnography and portable device monitoring (whatever is applicable)

| PSG | PSG | PSG | Portable | Portable | Portable | Portable | Portable | Portable
Author, Year Country (UI) | Equipment | Channels^A^ | Setting | Type | Name (equipment) | Channels^A^ | Setting and timing | Attended | Hookup

A Describe Flow and Effort channels / indicate nd if not described in the study

D. Interpretation of facility-based polysomnography and portable device monitoring (whatever is applicable)

| PSG | PSG | PSG | PSG | Portable | Portable | Portable | Portable
Author, Year Country (UI) | Scoring^A^ | Definition of breathing event^B^ | Denominator | Rater experience | Scoring^A^ | Definition of breathing event^B^ | Denominator | Rater experience

A Manual, combined manual and automated, or automated; or other description

B Indicate primary criteria and secondary criteria if they exist

E. Results: [NEW QUESTION] Relationship between baseline measurement of AHI or RDI and CPAP response or compliance

Author, Year Country (UI) | Criteria to start CPAP | N_Enrolled_ | N_Analyzed_ | Outcome | Baseline AHI [RDI] Mean (range) | Baseline for the outcome | Effect size (95% CI or p-value)^A^ | | Adjustments^B^ | Comments

A For example, the beta from a linear regression; the OR from a logistic regression; INDICATE THE CHANGE IN THE AHI/RDI THAT CORRESPONDS TO THE EFFECT SIZE

B Which adjustments (if any) were used

F. Results: Concordance [agreement between measurements – assume no gold standard]

Author, Year Country (UI) | Comparison | N_Enrolled_ | N_Analyzed_ | Concordance Metric^A^ | Value (95% CI or LOA)

A Bland Altman plot; Limits of Agreement; NOT correlation coefficients and OLS regression

G. Results: Diagnostic performances (Portable vs PSG; automated vs manual or combined manual and automated) [assumes gold standard]

Author, Year Country (UI) | Comparison (Index vs GS) | Index cutoff | Gold standard cutoff | TP: Index(+) & GS(+) | FN: Index(-) & GS(+) | FP: Index(+) & GS(-) | TN: Index(-) & GS(-) | ROC AUC | ROC Q* | Other

H. Narrative Questions information

Author, Year Country (UI) | Comparison | Necessity of channels used for Sleep Staging | Necessity of channels used for Airflow Estimation | Errors from unattended use | Errors from automated scoring

I. Narrative Questions information

Author, Year Country (UI) | Comparison | Complications and harms | Patient education | Data loss details

J. Methodologic quality (Assert that the study is prospective and there is no verification bias!)

Author, Year Country (UI) | Consecutive patients | Blinding to clinical information | Blinding to other test | Random test order or simultaneous testing | Clear description of studied population | Data loss (%) | Quality

## Data extraction form for studies that were assessed for errors, data loss, harms and adverse events

Author, Year Country (UI) | Sleep study (Comparison)^A^ | Attended | Hookup | N total | Errors, general | Errors from unattended use | Errors from automated scoring

A Just state if the comparators if study is a comparative one; Report details of the channels gathered as in the other form

Author, Year Country (UI) | Sleep study (Comparison)^A^ | Attended | Hookup | N total | % Data loss overall | Data loss details^B^ | Comment

A Just state if the comparators if study is a comparative one; Report details of the channels gathered as in the other form

B State in separate lines data loss in laboratory PSG and portable; if given, also in separate lines data loss per channel

Author, Year Country (UI) | Sleep study (Comparison)^A^ | Attended | Hookup | N total | % Harms | Harms and complications details^B^ | Comment

A Just state if the comparators if study is a comparative one; Report details of the channels gathered as in the other form

B State in separate lines harms in laboratory PSG and portable, and define them in the details box

REMEMBER:

NO RETROSPECTIVE STUDIES

A STUDY REPORTING NOTHING AT ALL DOES NOT QUALIFY; IF STUDY ASSESSED E.G. FOR ERRORS BUT FOUND NONE, STUDY QUALIFIES