# Detailed search strategy

The following search strategy was used in OVID MEDLINE. In fact, interim searches were performed during the writing of the Technology assessment, because additional questions were added in the meanwhile. The current strategy yields all citations that were identified with the interim searches. The last search was conducted on 28 February 2007.

Appendix Table 1 Detailed search strategy for OVID MEDLINE

Number | Search Terms
1 | exp Sleep apnea, Obstructive/ or exp Sleep Apnea Syndromes/
2 | Airway resistance.mp.
3 | exp snoring/
4 | Upper airway resistance syndrome.mp.
5 | Respiratory disturbance.mp.
6 | or/1–5
7 | exp Continuous Positive Airway Pressure/ or CPAP.mp.
8 | exp Polysomnography/
9 | Polysomnography.tw.
10 | polysomnograph$.tw.
11 | psg.tw.
12 | exp Oximetry/
13 | exp Monitoring, Physiologic/
14 | autoset.mp.
15 | or/8–14
16 | 6 and 15
17 | exp "sensitivity and specificity"/
18 | exp Predictive Value of tests/
19 | exp ROC curve/
20 | exp Mass Screening/
21 | exp diagnosis/
22 | exp reproducibility of results/
23 | exp false negative reactions/ or false positive reactions/
24 | Predictive value.tw.
25 | (sensitivity or specificity).tw.
26 | Accuracy.tw.
27 | Screen$.tw.
28 | Diagno$.tw.
29 | Roc$.tw.
30 | Reproducib$.tw.
31 | (false positive or false negative).tw.
32 | Likelihood ratio.tw.
33 | di.fs.
34 | or/17–33
35 | exp Evaluation Studies/
36 | or/34–35
37 | 36 and 16
38 | limit 37 to (addresses or bibliography or biography or case reports or congresses or consensus development conference or consensus development conference, nih or dictionary or directory or editorial or festschrift or government publications or interview or lectures or legal cases or legislation or news or newspaper article or overall or patient education handout or periodical index)
39 | 37 not 38
40 | limit 39 to human
41 | limit 40 to english language
42 | limit 41 to "all adult (19 plus years)"
43 | 41 not 42
44 | limit 43 to "all child (0 to 18 years)"
45 | 41 not 44
46 | remove duplicates from 45