# Summary

Obstructive Sleep Apnea-Hypopnea Syndrome (OSAHS), or Obstructive Sleep Apnea -OSA, is characterized by sleep disturbances secondary to upper airway obstruction. OSAHS is prevalent in two to four percent of middle-aged adults, and has been associated with daytime somnolence, cardiovascular morbidity, diabetes and other metabolic abnormalities, and increased likelihood of accidents and other adverse outcomes. The prevalence of OSAHS in older adults (65 years or older) is believed to be higher than the aforementioned estimates, but it is not as well studied. In fact, there are contradictory data suggesting that OSAHS prevalence levels off after the age of 65 years; a plausible explanation is that fewer new cases are identified among older adults. Continuous positive airway pressure (CPAP) is the commonly used treatment (additional interventions exist, but are not used or indicated in the majority of patients).

The reference standard for the diagnosis of OSAHS is facility-based polysomnography (PSG), a comprehensive sleep study that records and evaluates a variety of cardiorespiratory and neurophysiologic signals during sleep time. It quantifies the severity of disturbances with the Apnea-Hypopnea Index (AHI). Higher AHI values imply more severe sleep disturbances. Typically, a value of 15 events/hour of sleep or more is considered to be suggestive of OSAHS. Note that an AHI suggestive of OSAHS is not sufficient for the diagnosis of the condition, as the severity of symptoms has to be accounted for, and other conditions affecting sleep may need to be excluded.

Portable monitors have been developed in an effort to substitute for the more costly facility-based PSG. According to the data recorded, monitors are classified into different categories. Facility-based PSG is a type I monitor. Type II portable monitors record the same data as facility-based PSG, albeit using fewer channels. Type III portable monitors are less comprehensive, since they do not record neurophysiologic sleep staging information. Type IV portable monitors are those that fail to meet criteria for type III devices (i.e., they do not record at least two respiratory channels).

This technology assessment is based on a systematic review of the literature. In total 95 studies were included. Eligible studies assess the ability of sleep studies at baseline to predict response to CPAP treatment or CPAP use; the comparison of measurements with portable monitors and facility-based PSG; and the safety of sleep studies. We note that the current technology assessment focuses on adult patients, and did not consider pediatric populations.

Baseline AHI is only modestly associated with response to CPAP or CPAP use among people with high (pre-test) probability for OSAHS. The same is true for other indices obtained from sleep studies such as the mean or minimum O_2_ saturation, apnea index, hypopneas index, frequency of arousals and other quantities. Note that none of the eligible studies assessed hard clinical outcomes (i.e., mortality, myocardial infarctions, strokes and similar outcomes).

Based on limited data, type II monitors may identify AHI suggestive of OSAHS with high positive likelihood ratios (>10) and low negative likelihood ratios (>0.1) both when the portable monitors were studied in the sleep laboratory and at home. Type III monitors may have the ability to predict AHI suggestive of OSAHS with high positive likelihood ratios and low negative likelihood ratios for various AHI cutoffs in laboratory-based PSG, especially when manual scoring is used. The ability of type III monitors to predict AHI suggestive of OSAHS appears to be better in studies conducted in the specialized sleep unit compared to studies in the home setting. Studies of type IV monitors that record at least three bioparameters showed high positive likelihood ratios and low negative likelihood ratios. Studies of type IV monitors that record one or two bioparameters also had high positive likelihood ratios and low negative likelihood ratios, at least for selected sensitivity and specificity pairs from ROC curve analyses.

Similarly to type III monitors, the ability of type IV monitors to predict AHI suggestive of OSAHS appears to be better in studies conducted in specialized sleep units. However, Medicare beneficiaries are older than the studied subjects (the median average age was approximately 50 years in the analyzed studies), and may have more often comorbidities that affect sleep (i.e., non-OSAHS conditions such as cardiac insufficiency; chronic obstructive pulmonary disease; obesity hypoventilation syndrome; or Periodic Limb Movements in Sleep and Restless Leg Syndrome). These conditions may be misdiagnosed as OSAHS by sleep monitors that do not record channels necessary for the differential diagnosis from OSAHS. Therefore, some type III and type IV monitors may yield more false positives among Medicare beneficiaries, compared to what was observed in the assessed studies. We stress that in the assessed studies the frequency of patients with the aforementioned comorbidities was very low (in some these patients were clearly excluded, in the remaining the frequency was very low or not reported at all).

For studies in the home setting, there is no direct data on whether and to what extent technologist support and patient education affect the comparison of portable monitors with facility-based PSG.

Overall, manual scoring or manual editing of automated scoring seems to have better agreement with facility-based PSG compared to manual scoring in the studies that assessed both scoring methods. We note that the automated scoring algorithms may vary across different monitors, or even with the specific software version or settings. Thus their ability to recognize respiratory events may differ.

We did not identify detailed data on the specific types of errors that are directly related to automated or manual scoring. No studies associated directly any specific errors with unattended use. However, signal loss was more often observed in home studies, and one study associated discrepancies in the AHI measurement with poor quality airflow signals in the unattended home-based recordings.

The rate and severity of adverse events in sleep studies is low. In a large study of over 16,000 facility-based PSG complications were identified in less than 0.5% of the recordings. Complications were not reported in the remaining studies, and mostly minor harms were reported to the FDA adverse events database. This conclusion applies to both facility-based PSG and to portable monitors in various settings, including the home setting.

Rates of unsatisfactory studies and data corruption are higher for portable monitors in the home setting, compared to facility-based PSG, or portable monitors in the sleep laboratory setting. This may be attributed to user errors during device operation or probe hook-up for home studies, and also to the absence of an attending technologist.